# APPENDIX J CFIR 2.0 DOMAIN DETAILS

Study | Individual Barriers Identified | Innovation Domain | Outer Setting Domain | Inner Setting Domain | Individuals Domain | Implementation Process Domain
Barrier Categories
Challenges With Data Collection and Documentation
Berish, 2023, 36129432 | Unspecified data collection and documentation issues | | | | | Planning; Reflecting & Evaluating: Implementation
Guth, 2020, 32976620 | Lack of efficiency of processes, leading to missing screening data | | | Structural Characteristics: Work infrastructure | | Planning
Pohnert, 2023, 36134714 | Lack of confidence with documentation | | | | Roles: Innovation deliverers; Characteristics: Capability | Engaging: Innovation deliverers
Difficulty Changing Culture, Engaging Other Team Members, or Establishing New Processes
Wismann, 2024, 38488173 | Establishing new workflows | | | Structural Characteristics: Work infrastructure | | Adapting
Wismann, 2024, 38488173 | Challenges with deprescribing | | | Culture; Access to knowledge and information | Roles: Innovation deliverers; Implementation team members; Characteristics: Capability; Motivation
Tewary, 2023, 36062563 | Overall difficulty in changing the culture of established healthcare system | | | Relative Priority; Culture
Vonnes, 2023, 37783590 | Need for engaging pharmacists | | | | Other Implementation Support
Vonnes, 2023, 37783590 | Need to establishing processes for referral to appropriate follow up care after cognitive screening | | | Structural Characteristics: Work infrastructure | | Tailoring Strategies; Adapting
Lack of Buy-In or 4Ms Knowledge
Wismann, 2024, 38488173 | Lack of physician buy-in | | | | Roles: Mid-level leaders; Implementation team members; Characteristics: Motivation
Wismann, 2024, 38488173 | Unfamiliarity with asking about what matters most | | | Access to knowledge and information | Characteristics: Compatibility
Pohnert, 2023, 36134714 | Providers lacking knowledge of their own performance in 4Ms. | | | | | Reflecting and evaluating implementation
Tewary, 2023, 36062563 | Getting provider buy-in for documentation | | | | Roles: Innovation Deliverers; Characteristics: Motivation
Patient Preferences
Wismann, 2024, 38488173 | Too much information in one visit | | | Structural Characteristics: Work infrastructure; Compatibility
Garbarino, 2023, 38038359 | Patient preferences | | | Relative Priority | Roles: Innovation Recipients; Characteristics: Motivation | Tailoring Strategies
Garbarino, 2023, 38038359 | Inconvenience to patients if multiple visits were required | | | Relative Priority | Roles: Innovation Recipients | Tailoring Strategies
Tewary, 2023, 37489318 | Making contact with patients | | | | | Engaging
Scheduling/Time Constraints
Wismann, 2024, 38488173 | Short visit length; time limitations | | | Available Resources; Structural Characteristics: Work infrastructure
Wismann, 2024, 38488173 | Nursing staff shortages | | | Available Resources; Structural Characteristics: Work infrastructure
Wismann, 2024, 38488173 | Competing clinical priorities | | | Structural: Work infrastructure; Relative priority
Tewary, 2023, 36062563 | Time constraints for documentation and comprehensive evaluation of patients restricting the implementation of best practices | | | Relative Priority | Available Resources
Tewary, 2023, 36062563 | Barriers to telehealth visits: scheduling constraints | | | Structural Characteristics: Work infrastructure; Compatibility
Technology Barriers
Wismann, 2024, 38488173 | EHR limitations | | | Structural: Information technology infrastructure
Tewary, 2023, 37489318 | Inability to fully assess mobility and environment due to method of visit (telehealth) | | | | | Tailoring Strategies
Tewary, 2023, 36062563 | Barriers to telehealth visits: (Technology, computer literacy, broadband) | | | Structural Characteristics: Work infrastructure; Compatibility
Other
Tewary, 2023, 36062563 | Reduced training participation due to COVID | | Critical Incidence | Relative Priority
Wismann, 2024, 38488173 | Need for clinical support tools | | | Structural Characteristics: Information technology infrastructure; Physical infrastructure; Available Resources
Tewary, 2023, 37489318 | Access to interpreter services for after hours visits | | | Available Resources | Other implementation support
Tewary, 2023, 37489318 | Difficult to implement 4Ms with medically complex or cognitively impaired patients or those who require more time in their appointments for other reasons | | | Available Resources; Innovation Recipients; Relative priority
Facilitator Categories
Buy-In
Wismann, 2024, 38488173 | Leadership prioritization | | | Relative Priority | Roles: Mid-Level Leaders; Characteristics: Motivation
Wismann, 2024, 38488173 | Team buy-in and shared goals | | | | Roles: Innovation deliverers; Characteristics: Motivation
Berish, 2023, 36129432 | Leadership buy-in | | | | Roles: High-Level Leaders; Characteristics: Motivation
Garbarino, 2023, 38038359 | Clinical team buy-in | | | | Roles: Mid-Level Leaders; Implementation team members; Characteristics: Motivation
Lundy, 2021, 33275785 | Clinical-team buy-in | | | | Roles: High-level leaders; Mid-level leaders; Implementation team members; Characteristics: Motivation
Admin Support or Existing Infrastructure
Wismann, 2024, 38488173 | Modification of EHR templates to prompt documentation | | | Structural Characteristics: IT infrastructure | | Adapting
Wismann, 2024, 38488173 | Monthly meetings with practice facilitator | | | | Implementation Facilitators | Teaming
Wismann, 2024, 38488173 | QI measure review | | | | | Reflecting and Evaluation: Implementation
Guth, 2020, 32976620 | Existing weekly high-risk rounds | | | Structural Characteristics: Work Infrastructure; Relational connections; Communications
Lundy, 2021, 33275785 | Administrative support | | | Structural Characteristics: Work infrastructure | Roles: Other Implementation Support; High level leader; Characteristics: Motivation
Clinical Team Knowledge of 4Ms
Wismann, 2024, 38488173 | Importance of trainee exposure to 4Ms | | | Culture: Learning-Centeredness; Access to knowledge and information
Pohnert, 2023, 36134714 | Clinical team knowledge of 4Ms | | | Access to Knowledge & Information | Roles: Implementation team members; Characteristics: Capability
Stakeholder Partnerships/Community Support
Lundy, 2021, 33275785 | Regular interaction between stakeholders | | | | | Teaming; Engaging: Innovation Deliverers
Lundy, 2021, 33275785 | Availability of community-based supports | | Partnerships & Connections; Local Conditions
Pohnert, 2023, 36134714 | Stakeholders partnerships | | Partnerships & Connections | | | Teaming
Other
Pohnert, 2023, 36134714 | Effective UI design | | | Structural Characteristics-Information Technology Infrastructure
Wismann, 2024, 38488173 | Visual reminders to cue providers | | | | | Tailoring Strategies
Wismann, 2024, 38488173 | Patient resources | | Partnerships & Connections | Available Resources

Abbreviations. 4Ms=What Matters, Medication, Mentation, and Mobility; EHR=electronic health record; QI=quality improvement.