# APPENDIX I CONTEXTUAL FACTORS FOR AFHS IMPLEMENTATION (KQ1)

Study | Implementation Facilitators | Implementation Barriers | Uncategorized Contextual Factors
Wismann, 2024, 38488173^a^ | - Leadership prioritization; - Team buy-in and shared goals; - Modification of EHR templates to prompt documentation; - Monthly meetings with practice facilitator; - QI measure review; - Visual reminders to cue providers; - Patient resources; - Importance of trainee exposure to 4Ms | - Short visit length; time limitations; - Nursing staff shortages; - Lack of physician buy-in; - Competing clinical priorities; - Too much information in one visit; - Establishing new workflows; - EHR limitations; - Need for clinical support tools; - Challenges with deprescribing; - Unfamiliarity with asking about what matters most | NR
Berish, 2023, 36129432 ^b^ | - Leadership buy-in | - Unspecified data collection and documentation issues | NR
Garbarino, 2023, 38038359 ^b^ | - Clinical team buy-in | - Patient preferences; - Inconvenience to patients if multiple visits were required | NR
Guth, 2020, 32976620 ^b^ | - Existing weekly high-risk rounds | - Lack of efficiency of processes, leading to missing screening data | NR
Lundy, 2021, 33275785 ^b^ | - Administrative support; - Clinical-team buy-in; - Regular interaction between stakeholders; - Availability of community-based supports | NR | NR
Pohnert, 2023, 36134714 ^b^ | - Clinical team knowledge of 4Ms; - Stakeholder partnerships; - Effective UI design | - Providers lacking knowledge of their own performance in 4Ms.; - Lack of confidence with documentation
Powers, 2022, 36286213 ^b^ | NR | NR | - Clinical team engagement with the development of the dashboard
Tewary, 2023, 36062563 ^b^ | NR | - Barriers to telehealth visits:; ○ Technology; ○ Computer literacy; ○ Broadband; - Barriers to telehealth visits: Scheduling constraints; - Getting provider buy-in for documentation; - Time constraints for documentation and comprehensive evaluation of patients restricting the implementation of best practices; - Reduced training participation due to COVID-19; - Overall difficulty in changing the culture of established healthcare system | - Operational policies; - Provider constraints such as time to chart and AFHS documentation; - Concerns about infection; - Limited face-to-face patient visits with providers
Tewary, 2023, 37489318^b^ | NR | - Making contact with patients; - Inability to fully assess mobility and environment due to method of visit (telehealth); - Access to interpreter services for afterhours visits; - Difficult to implement 4Ms with medically complex or cognitively impaired patients or those who require more time in their appointments for other reasons | NR
Vonnes, 2023, 37783590 ^b^ | NR | - Need for engaging pharmacists; - Need to establishing processes for referral to appropriate follow up care after cognitive screening | NR

Notes.

a Study explicitly assessing contextual factors

b Study that mentioned contextual factors without explicit examination of these.

Abbreviations. 4Ms=What Matters, Medication, Mentation, and Mobility; AFHS=Age-Friendly Health System; EHR=electronic health record; NR=not reported; Qi=quality improvement; UI=user interface.