# APPENDIX H BASELINE CHARACTERISTICS

Author, Year, PMID, Study Design | Subject Group | N | Age | Demographics [Male %, Race or Ethnicity %] | Other
Berish, 2023, 36129432, (Baseline-later Time point)^a,b^ | Workforce participants | 368 | NR | NR | Included primary health network employees, students, students who are also primary health network employees, community group members, college of nursing faculty, area agency on aging, specialty providers
Berish, 2023, 36129432, (Baseline-later Time point)^a,b^ | Patients seen | 6924^c^ | 74.3 (6.9) | NR | NR
Garbarino, 2023, 38038359, Single group (Pre-post) | Primary care clinic workforce | NR | NR | NR | Number of patients seen annually; ~ 2500 patients (~ 571 enrolled in Medicare)
Garbarino, 2023, 38038359, Single group (Pre-post) | Patients seen | 116 | <70: 25%; 71–75: 32%; 76–80: 25%; 81–85: 11%; >85: 7% | Male: 39%; White: 96%; Asian: 1%; Others: 2%; Declined: 2% | NR
Guth, 2020, 32976620, Single group (Pre-post) | Healthcare providers | 11 | NR | NR | NR
Guth, 2020, 32976620, Single group (Pre-post) | New patients | 122 | NR | NR | NR
Lundy, 2021, 33275785, Single group (Post only) | NR | NR | NR | NR | NR
Lundy, 2021, 33275785, Single group (Post only) | Patients seen | 1,326 | ≤65 | NR | Frailty: 36.5%; Sarcopenia: 42.1%; Anorexia risk: 26.1%; Dementia: 28.1%
Pohnert, 2023, 36134714, NRCS^d^ | Approximately 1,100 MinuteClinics | 2901^e^ | NR | NR | NR
Pohnert, 2023, 36134714, NRCS^d^ | Patients eligible for 4Ms | 324,245 | NR | NR | NR
Powers, 2022, 36286213, Single group (Post only) ^f^ | Workforce VA Medical Center clinics | 2 | NR | NR | NR
Powers, 2022, 36286213, Single group (Post only) ^f^ | Patients seen | 176 | NR | NR | NR
Tewary, 2023, 36062563, Single group (Pre-post) | Primary care clinic providers who received training | 80 | NR | Male: 38%^g^; White: 44% ^g^; Hispanic: 12% ^g^; Others: 88% ^g^ | Clinic personnel, physicians, medical assistants, and nurses at identified clinics
Tewary, 2023, 36062563, Single group (Pre-post) | Patients seen at these clinics | NR | ≥65 | NR | NR
Tewary, 2023, 37489318, Single group (Pre-post)^h^ | 1 university clinic and 1 health center clinic | NR | NR | NR | NR
Tewary, 2023, 37489318, Single group (Pre-post)^h^ | Patients seen | 146 | ≥65 | NR | NR
Vonnes, 2023, 37783590, Single group (Post only) | Senior Adult Oncology Program at a cancer center | NR | Facility patients that are over the ≥65: 49% | NR | Facility had 97 geriatric resource nurses and 134 geriatric patient care associates who are unlicensed geriatric care experts.
Vonnes, 2023, 37783590, Single group (Post only) | Patients seen | 5500 | NR | NR | NR
Wismann, 2024, 38488173, Single group (Pre-post) | 5 primary care clinics (geriatrics, internal medicine, 3 family medicine clinics) | NR | Percent of patients 65+: 11 to 98% | Patients see at clinics:; White: 47.2 to 91.8%; Black: 4.2 to 40%; American Indian: 1.2 to 2.1%; Asian: 1.3 to 3.4%; Native Hawaiian/Pacific Islander: 0.2 to 0.8%; Hispanic: 2.7 to 9.2%; Not reported: 1.4 to 7.6% | 3 academic training sites, 2 non-academic training sites;; 3 urban sites, 2 rural sites
Wismann, 2024, 38488173, Single group (Pre-post) | Patients | 5807 | ≥65 | NR | NR

Notes.

a Initial implementation phase to a later time point

b Study compared results at 3 pilot sites to 18 sites after they implemented strategies at a later date. Because all 21 sites implemented the same strategies, we reported this as a single group pre-post study

c Patients seen from 3 pilot sites and 18 comparison sites

d Reported mostly single group outcomes, but also compared sites that implemented 2 specific strategies (Virtual Clinic strategy and PDSA strategy) to sites that did not implement the strategies, therefore used as single group (baseline-later time point) design for sites that did not already have AFHS and NRCS for sites with existing AFHS

e Providers completed the orientation introducing 4Ms care

f Study compared a site that incorporated a templated note as part of their electric health record to a site that implemented AFHS but did not use a templated note. Because the overall strategies and 4Ms assessments were different between sites, we reported this as a single group study

g Of participants provided feedback by completing the knowledge survey (N=16)

h Study reported 2 different strategies implemented at 2 different sites, which we reported as a single group pre-post study, though 1 site had post-only data.

Abbreviations. NR=not reported; NRCS=nonrandomized comparative study.