# APPENDIX G DESIGN DETAILS

Author, Year, PMID | Study Design | Setting, Funding | Study Years | Inclusion
Berish, 2023, 36129432 | Single group; (Baseline-later time point)^a,b^ | Outpatient Clinic, Non-industry | 2020–2021 | 21 Federally Qualified Health Centers (FQHC) clinical sites.
Garbarino, 2023, 38038359 | Single group (Pre-post) | Outpatient Clinic, Non-industry | 2019–2022 | A patient centered primary care practice in a northeastern, increasingly urban region of the United States.
Guth, 2020, 32976620 | Single group (Pre-post) | Outpatient Clinic, Not reported | 2018 – 2019 | An ambulatory care practice that specializes in the case of older adults with medical, medication, and psychosocial needs during the study period.^c^
Lundy, 2021, 33275785 | Single group (Post only) | Outpatient Clinic (Rural Primary Health Care), Non-industry | 2015–2019 | Workforce at an outpatient clinic who attended at least 5 of 8 class sessions.
Pohnert, 2023, 36134714 | NRCS^d^ | Convenient care clinic, Non-industry | 2020–2022 | MinuteClinics located in 35 states and DC.
Powers, 2022, 36286213 | Single group^e^ (Post only) | Outpatient Clinics,^f^ Non-industry | 2021–2021 | Workforce at 2 VA Medical Centers.
Tewary, 2023, 36062563 | Single group (Pre-post) | Outpatient Clinic, Non-industry | 2019–2020 | Clinic personnel, physicians, medical assistants, and nurses at identified clinics.
Tewary, 2023, 37489318 | Single group (Pre-post)^g^ | Outpatient Clinic, Non-industry | 2021–2023 | Two primary care clinics in South Florida that have both been designated as age-friendly clinics by the Institute of Healthcare Improvement (IHI).
Vonnes, 2023, 37783590 | Single group (Post only) | Cancer center, Not reported | 2019–2023 | Senior Adult Oncology Program (SAOP).
Wismann, 2024, 38488173 | Single group (Pre-post) with Qualitative Component | Outpatient Clinics, Non-industry | 2020–2023 | Primary care clinics within an academic health system. ^c^

Notes.

a Initial implementation phase to a later time point

b Study compared results at 3 pilot sites to 18 sites after they implemented strategies at a later date. Because all 21 sites implemented the same strategies we reported this as a single group pre-post study

c At MedStar Center for Successful Aging (CSA)

d Reported mostly single group outcomes, but also compared sites that implemented 2 specific strategies (Virtual Clinic strategy and PDSA strategy) to sites that did not implement the strategies, therefore used as single group (baseline-later time point) design for sites that did not already have AFHS and NRCS for sites with existing AFHS

e Study compared a site that incorporated a templated note as part of their electric health record to a site that implemented AFHS but did not use a templated note. Because the overall strategies and 4Ms assessments were different between sites, we reported this as a single group study

f Two VA Medical Centers

g Study reported 2 different strategies implemented at 2 different sites, which we reported as a single group pre-post study, though 1 site had post-only data

h University of Oklahoma (OU) Health.

Abbreviations. NRCS=nonrandomized comparative study.