# APPENDIX F RELEVANT CONFERENCE ABSTRACTS

Authors, Year, Key Question | Strategy Implemented | Design Details (Setting, Study Years, Eligibility Criteria) | Sample Details | Overview of Results
Arany, 2023, KQ2 | Dental Clinic patients receiving the 4Ms assessment - Developed dental definition of the 4Ms and incorporated into a templated note | Setting: Dental Clinic;; Study Years: 2021–2021 (8 months);; Eligibility criteria: NR | N=100 patients;; Age= 65+ years old | Process Measures (KQ2); - Patients agreed with comprehensive dental treatments, including extractions (What Matters)= 78/100 (78%); - Patients who had a fall risk (Mobility)= 70/100 (70%); - Patients that had polypharmacy (Medication)= 8/100 (8%); - Patients taking high risk medications (Medication)= 45/100 (45%); Outcome Measures (KQ2); - Patients unable to brush alone (Mobility)= 23/100 (23%); - Patients who screened positive for cognitive impairment (Mentation)= 5/100 (5%)
Carrico, 2022, KQ1 & KQ2 | Geriatric focused ECHOs with an emphasis on the 4Ms of Age-Friendly Health Systems (no further details provided) | Setting: Unclear;; Study Years: 2019-NR;; Eligibility criteria: NR | Geriatric Workforce Enhancement Programs= 6; Participants engaged= over 7, 500 from 64 professions | Barriers (KQ1); - Challenges in recruiting case presenters and maintaining consistent engagement of participants.; Process Measures (KQ2); - Practice change data indicates improved ability to assess and address the 4Ms (Other) (p=NR)
Carvalho Do Amaral, 2023, KQ2 | Clinic A: Clinic health professionals trained on AWV and 4Ms Healthcare system integration; AWV template integrated into EPIC EmR system; Clinic B Development of an implementation plan to optimize geriatric care, which included creation of a visit template with all aspects of AWV and 4Ms and staff training to ensure engagement and role clarity. | Setting: Primary care clinics sites affiliated with an academic institution located in urban underserved areas of Chicago, serving mostly Latinx and Black or African American communities;; Study Years: 2021–2022; Eligibility criteria: geriatric care | Total N= 437 chart audits | Process Measures (KQ2); - AWVs (Clinic A) (Other)= 26/100 (26%); - Falls screenings (Clinic A) (Mobility)= 22/100 (22%); - Dementia screenings (Clinic A) (Mentation)= 9/100 (9%); - Depression screenings (Clinic A (Mentation))= 18/100 (18%); - Polypharmacy screenings (Clinic A) (Medication)= 7/100 (7%); - Advanced Directive screenings (Clinic A) (What Matters)= 11/100 (11%); - Clinic B= NR
Casey, 2023, KQ2 | A 4-week geriatric ‘mini-fellowship’ structured using the Age-Friendly Health System 4Ms principles of care. | Setting: Health system clinics;; Study Years: 2018;; Eligibility criteria: NR | Total N= about 3,600 patients 65+ years old;; 13 providers | Process Measures (KQ2); Change from 12 months before vs 12 months after intervention:; - Percent of patients with fall risk intervention (Mobility)= 34% vs 60%; - Percent of patients with documented goals of care (What Matters)= 0% vs 2%; - Discontinuation of high-risk medication (Medication)= 34%^a^; Outcome Measures (KQ2); - Percent with new dementia diagnosis on problem list (Mentation)= 3.0 vs 4.3%; Structural Measures (KQ2); - Cost savings for the health care system (per year) (Other)= at least $560,000/year
Dobert, 2020, KQ2 | Geri Pal Interprofessional Team (IPT) who received Geriatrics and Palliative Care training and weekly geriatrician consultation, with integration of 4Ms in the care delivery model. | Setting: Outpatient Clinic;; Study Years: NR;; Eligibility: ≥ 3 NP visits | N=47 patients | Process Measures (KQ2); - Screened for depression with PHQ2 (Mentation)= 45 (96%); - Had a cognition screening (AD8, MiniCog, MOCA, or MMSE) (Mentation)= 43 (91%); - Mobility assessed using TUG (Mobility)= 37 (74%); - Had a valid HCP (What Matters)= 44 (94%); - Introduced to Goals of Care (GOC) using the Conversation Starter Kit (What Matters)= 28 (55%); - Had GOC discussion (What Matters)= 28 (60%); - Had a valid MOLST (What Matters)= 14 (30%); Structural Measures (KQ2); - Average total acute care cost per patient 6 months pre/6 months post 1st NP visit (Other)= $5,459 vs $3,967; - Number of inpatient hospitalizations 6 months pre/6 months post 1st NP visit (Other)= 29 to 15; - Number of emergency room visits 6 months pre/6 months post 1st NP visit (Other)= 21 to 13
Dobert, 2021, KQ2 | IPT had twice monthly meetings to ensure 4Ms Care remains consistent. PDSA cycles include: increased flow of referrals, RN role refinement, identification of training needs, improved documentation with new care plan, and visit flow chart. | Setting: Community Health Centers Program; Study Years: NR; Eligibility criteria: NR | N= 167 patients | Process Measures (KQ2); - Made medication recommendation (Medication)s= 68%; - 4Ms measures completed: Baseline vs follow up:; ○ Health Care Proxy (What Matters)= 57% vs 88%; ○ MOLST (What Matters)= 10% vs 25%; - Prescribed potentially inappropriate medication (Medication):; ○ >1= 73%; ○ >2= 49%; ○ >4= 92%; - Had a reduction in total number of medications (Medication)= 19%; ○ Fall Risk Diagnosis from baseline to follow up (Mobility)= 5% vs 88%; Outcome Measures (KQ2); - 4Ms measures completed: Baseline vs follow up:; ○ Acute Dementia Diagnosis (Mentation)= 33% vs 63%
Drost, 2020, KQ2 | High Intensity Clinic (HIC) that implements the 4Ms in patients with multiple chronic illnesses who have complex care needs. Team consists of geriatric physicians, a pharmacist, a social worker, a nurse care manager, and a dedicated medical assistant. | Setting: High Intensity Clinic (HIC);; Study Years: NR;; Eligibility criteria: Eligibility for the HIC was based on utilization of the emergency room (ER) and hospital or a high score on a geriatric risk tool that tabulates geriatric syndromes. | N=25 patients;; Age: 70 years old (range=47 to 87 years old | Process Measures (KQ2); - ER and admission visits (Other) = decreased by 57% during the evaluation period (p=0.016, 95% CI (−2.44, −0.27)); - Average number of office visits during 6 month intervention (Other)= 5.6; - Average number of medication changes in 6 month intervention window (Medication)= 6.7; - Average number of provider-initiated phone calls post intervention (Other)= 4.6; Outcome Measures (KQ2); - Average number of uncontrolled symptoms per patient (preintervention vs post-intervention) (Other)= 8 vs. 5
Khanna, 2022, KQ2 | 4Ms implementation: “What Matters” was assessed by providers asking “What Matters the most to you;” potentially inappropriate Medications were identified using the Beers list; Mentation was evaluated using the Mini-Cog; and Mobility was assessed using timed up and go (TUG) test. | Setting: Outpatient geriatric clinic;; Study Years: 2021; Eligibility criteria: NR | N=121 patients | Process Measures (KQ2); - Patients asked “what matters” (What Matters)= 103/121 (85%); - Providers reviewed Medications (Medication)= 118/121 (98%); - Providers conducted a Mini-Cog (Mentation)= 78/121 (64%); - Providers used the TUG test (Mobility)= 105/121 (87%); - Patients receiving further cognitive evaluation (among 14 patients with abnormal Minicog) (Mentation)= 2/14; - Patients receiving home care referrals (among 14 patients with abnormal Minicog) (Mentation)=2/14; - Intervention with devices, referrals or home services in patients with abnormal TUG (Mobility)= 19/51 (37%); - Patients with potentially inappropriate Medications (Medication)= 39/118 (33%); - Patients with medications either discontinued or reduced (Medication)= 10/39 (26%); Outcome Measures (KQ2); - Patients with abnormal MiniCog (Mentation)= 14/78 (18%); - Patients with abnormal TUG (Mobility)= 51/105 (73%)
Kim, 2022, KQ2 | Training about 4Ms action plan in telehealth-based primary care. “What matters” measured through advanced care plan, Medications assessed through deprescribing or reducing high risk medications, mentation assessed through depression/cognition assessment and brief counseling, and mobility assessed though mobility/home safety and referral | Setting: Urban primary care provider;; Study Years: 2020– 2021;; Eligibility criteria: NR | 14 primary care providers trained; 184 patients (60+) assessed;; Ethnically/racially diverse population 39.7% (73/184) | Process Measures (KQ2); Overall:; - Advanced care planning discussed (What Matters)= 79.9%; - Medication assessed (Medication)= 16.8%; - Mobility assessed (Mobility)= 46.2%; - Mentation assessed (Mentation)= 14.7%; - 4Ms action plans not discussed (Other)= 61.4%; White vs Non-White patients:; - Advanced care planning discussed (What Matters)= 84.7% vs 72.6%; - Medication assessed (Medication)= 23.4% vs 6.8%; - Mobility assessed (Mobility)= 61.3% vs 26.0%; - Mentation assessed (Mentation)= 19.8% vs 6.8%; - 4Ms action plans not discussed (Other)= 60.4% vs 63.0%
O’Hara, 2021, KQ1 | Not specified; achieving age friendly status | Settings: Geriatrics-staffed, primary care clinics in two different health systems, a Veterans Affairs-based clinic (VA) and a safety-net hospital-based primary care clinic;; Study Years: NR; Eligibility Criteria: NR | N= 2 healthcare systems | Barriers (KQ1); - Limited staffing, which resulted in task delegation being centralized around the provider.; Facilitators (KQ1); - Buy-in of clinic directors and staff; - Adequate staffing; - Distribution of assessment of the 4Ms across interprofessional team members
Rubino, 2021, KQ2 | Senior Strong, which provides screening, referral and health professional training around all 4Ms | Setting: Outpatient Clinic;; Study Years: 2020–2020; Eligibility: age 65+ | N= 15 patients served by the Senior Strong program; NR for usual care group | Process Measures (KQ2); - Depression screening (Senior Strong vs Usual Care) (Mentation)= 73.3% vs 32%; - Noted that similar results were seen for documentation of advance care planning discussions and falls screening
Vu, 2022, KQ1 | Not specified; age friendly community clinic | Setting: Urban, community-based, family medicine primary care clinic; Study Years: NR; Eligibility criteria: NR | NR | Barriers (KQ1); - Lack of support staff; - Lack of purposeful allocation of time; - Lack of knowledge and training surrounding the use of available screening methods, community resources, utilization of pharmacist expertise, and distribution of educational materials; Facilitators (KQ1); - Trained clinic staff and physicians who utilize screening measures during regular visits; - Focused geriatric clinic appointments related to 4Ms framework; - Involvement of all members of the care team
Vu, 2023, KQ1 | Not specified; clinic that has obtained Level 1 status | Setting: Community-based Primary Care Clinic; Study Years: NR; Eligibility criteria: NR | 65+ years old | Facilitators (KQ1); - Consistent utilization of the electronic health record system; - Trained clinic staff; - Involvement of all members of the care team; Barriers (KQ1); - Staffing; - Allocation of time to train the care team on how to utilize and apply the 4Ms; - Consistent emphasis on how to provide Age-Friendly, high-quality care to patients
Yang, 2023, KQ2 | Interprofessional education and telehealth training curriculum for primary care healthcare providers, informed by the 4Ms | Setting: A provider shortage area;; Study Years: 2021–2021; Eligibility criteria: Patients with mild to moderate dementia | N= 50 patients;; Age: 67–94 | Process Measures (KQ2); - Improvement in MIPS Dementia Caregiver Education and Referral (Mentation)= 15.6% vs 51.0%; - MIPS Advance Care Planning (What Matters)= 10.8% vs 42.8%; Structural Measures (KQ2); - Hospitalization-related healthcare cost (Other): Average cost saving of $22,135 per patient for those trained vs those without training

Notes.

a As reported in the figure presented in the abstract, percent of patients on high-risk medications = 35.7% versus 35.8%.

Abbreviations. 4Ms=What Matters, Medication, Mentation, and Mobility; AD8=Eight-item Informant Interview to Differentiate Aging and Dementia; AWV=annual wellness visit; ECHO=Extension for Community Healthcare Outcomes; EMR=electronic medical record; ER=emergency room; GOC=goals of care; HCP=health care proxy; HIC=high intensity clinic; IPT=interprofessional team; KQ=key question; MIPS=merit-based incentive payment system; MMSE=mini mental status exam; MOCA=Montreal Cognitive Assessment; MOLST=medical orders for life-sustaining treatment NP=nurse practitioner; PDSA=plan-do-study-act; PHQ2=patient health questionnaire-2; TUG=timed up and go test.