# APPENDIX E RISK OF BIAS ASSESSMENTS

Authors, Year, PMID (Design) | Blinding of Outcome Assessor | Incomplete Outcome Data (Attrition Bias) | Clear Reporting With No Discrepancies | Were Eligibility Criteria Clear? | Were Interventions Adequately Described? | Were The Outcomes Fully Defined? | NRCS & Single: Representativeness of the Cohort(S) | NRCS: Comparator Representativeness | NRCS: Adjustment for Confounders | Other Bias | Overall Risk of Bias
Berish, 2023, 36129432, (Baseline-later time point)^a,b^ | No (Low concern) | No (Low concern) | Yes (Low concern) | Yes (Low concern) | Yes (Low concern) | Yes (Low concern) | Unclear | | | No (Low concern) | Low
Garbarino, 2023, 38038359, Single group (Pre-post) | No (Low concern) | No (Low concern) | No (High Concern)^c^ | Yes (Low concern) | Yes (Low concern) | No (High Concern)^d^ | Yes (Low concern) | NA | NA | Yes (High Concern)^e^ | High
Guth, 2020, 32976620, Single group (Pre-post) | No (Low concern) | Unclear | No (High Concern)^f^ | Yes (Low concern) | Yes (Low concern) | No (High Concern)^g^ | Unclear | NA | NA | No (Low concern) | High
Lundy, 2021, 33275785, Single group (Post-only) | No (Low concern) | No (Low concern) | Yes (Low concern) | No (High Concern)^h^ | Yes (Low concern) | No (High Concern)^i^ | Unclear | NA | NA | Yes (High Concern)^j^ | High
Pohnert, 2023, 36134714, NRCS^k^ | No (Low concern) | No (Low concern) | Yes (Low concern) | Yes (Low concern) | Yes (Low concern) | No (High Concern)^l^ | Yes (Low concern) | Yes (Low concern) | Yes (Low concern) | No (Low concern) | Moderate
Powers, 2022, 36286213, Single group^m^ | No (Low concern) | No (Low concern) | No (High Concern)^n^ | No (High Concern)^o^ | Yes (Low concern) | Yes (Low concern) | Yes (Low concern) | | | Yes (High Concern)^j^ | High
Tewary, 2023, 36062563, Single group (Pre-post) | No (Low concern) | No (Low concern) | No (High concern)^p^ | No (High Concern)^o^ | Yes (Low concern) | Yes (Low concern) | Yes (Low concern) | NA | NA | No (Low concern) | High
Tewary, 2023, 37489318, Single group (pre-post)^q^ | No (Low concern) | No (Low concern) | Yes (Low concern) | Yes (Low concern) | Yes (Low concern) | Yes (Low concern) | Yes (Low concern) | NA | NA | Yes (High Concern)^r^ | Moderate
Vonnes, 2023, 37783590, Single group (Post-only) | No (Low concern) | Unclear | Yes (Low concern) | Yes (Low concern) | Yes (Low concern) | Yes (Low concern) | Yes (Low concern) | NA | NA | Yes (High concern)^j^ | High
Wismann, 2024, 38488173, Single group (Pre-post) | Yes(Low concern) | No (Low concern) | No (High Concern)^s^ | Yes (Low concern) | Yes (Low concern) | Yes (Low concern) | Yes (Low concern) | NA | NA | Yes (High Concern)^t^ | High

Notes.

a Initial implementation phase to a later time point

b Study compared results at 3 pilot sites to 18 sites after they implemented strategies at a later date. Because all 21 sites implemented the same strategies, we reported this as a single group pre-post study

c Only reported on one M

d Did not report on population seen by other physicians

e No inclusion of data for annual wellness visits not seen by RNs

f Lack of clarity in sample used for each outcome

g Compliance not fully defined

h Minimal information provided about those who were eligible to be included

i No information about measure cutoffs provided

j Data only reported for single time point

k Reported mostly single group outcomes, but also compared sites that implemented 2 specific strategies (Virtual Clinic strategy and PDSA strategy) to sites that did not implement the strategies, therefore used as single group (baseline-later time point) design for sites that did not already have AFHS and NRCS for sites with existing AFHS

l It was not clear how they defined “completion” of the 4Ms

m Study compared a site that incorporated a templated note as part of their electric health record to a site that implemented AFHs but did not use a templated note. Because the overall strategies and 4Ms assessments were different between sites, we reported this as a single group study

n Results reported in the text versus table were different; report of “intermediate” health factor without explanation of what this term means

o Not clear which patients were eligible or minimum information about those included

p Outcome tables included extra data without explanation of what these were

q Study reported 2 different strategies implemented at 2 different sites, which we reported as a single group pre-post study, though 1 site had post-only data

r Only reported post-intervention outcomes on a small number of patients

s Missing information from text and figures

t Different baseline years and follow-up times.