# APPENDIX D WALTZ CLUSTERS WITH EXAMPLE IMPLEMENTATION STRATEGIES (ERIC)

Waltz Strategy Cluster | Example Implementation Strategies (ERIC)
Use evaluative and iterative strategies | - Develop implementation tools for quality monitoring; - Conduct local needs assessments
Provide interactive assistance | - Facilitation; - Provide clinical supervision
Adapt and tailor to context | - Tailor strategies; - Use data experts
Develop stakeholder interrelationships | - Identify and prepare champions; - Build coalitions
Train and educate stakeholders | - Conduct ongoing trainings; - Develop educational materials
Support clinicians | - Create new clinical teams; - Remind clinicians
Engage consumers | - Prepare patients to be active participants; - Increase uptake or adherence
Utilize financial strategies | - Access new funding; - Develop alternate incentive structures
Change infrastructure | - Mandate change; - Change physical structures and equipment