# APPENDIX C STUDIES EXCLUDED DURING FULL-TEXT SCREENING, ARTICLES WHOSE CITATIONS WERE SEARCHED, AND IDENTIFIED CONFERENCE ABSTRACT CITATIONS

Citation and Reason for Exclusion
Abdallah M, Emmich M, Brennan M. Incorporating Age-Friendly Health System (AFHS) principles into internal medicine residents' continuity clinics. Journal of the American Geriatrics Society. 2020;68(SUPPL 1):S272. Annual Scientific Meeting of the American Geriatrics Society, AGS 2020. Long Beach, CA United States. No extractable data.
Adler-Milstein JR, Krueger GN, Rosenthal SW, Health system approaches and experiences implementing the 4Ms: Insights from 3 early adopter health systems. Journal of the American Geriatrics Society. 2023;71(8):2627–2639. Wrong setting/Not outpatient.37246845
Carney MT, Kwiatek S, Burns EA. Transforming health care: A large health organizations'journey to become an Age-Friendly Health System (AFHS) and beyond. Journal of the American Geriatrics Society. 2024;72(2):579–588. Wrong setting/Not outpatient.37927247
Dolansky MA, Pohnert A, Ball S, Pre-Implementation of the Age-Friendly Health Systems evidence-based 4Ms framework in a multi-state convenient care practice. Worldviews on Evidence-Based Nursing. 2021; 18(2): 118–128. Pre-implementation.33856117
Dolansky M, Kalsy M, Pohert A. Using The Socio-Technical Model of Health Information Technology Model To Improve Age Friendly Care. BMJ Open Ophthalmology. 2022;11 (Supplement 3):A15–A17. 2022 IHI Scientific Symposium. Online. Copublication or preliminary results of included study.
Dolansky MA, Pohnert A. The Intersection of Quality Improvement and Implementation Science: A Case Study. BMJ Open Quality. 2021;10(Supplement 2):A22–A24. Institute for Healthcare Improvement Scientific Symposium, IHI 2021. Virtual. Copublication or preliminary results of included study.
Dora MD, Haryanto J, Kholifah SN, Factor affecting the success of aged-friendly primary health care program for elderly in Surabaya City. Medico-Legal Update. 2020;20(2):673–677. No 4M implementation or not specific to 4Ms.
Dryden EM, Kennedy MA, Conti J, Perceived benefits of geriatric specialty telemedicine among rural patients and caregivers. Health Services Research. 2023;58(S1):26–35. No 4M implementation or not specific to 4Ms.36054487
Faul A, Powers J, Waters B, Using the 4M model of age-friendly healthcare to improve patient outcomes. In Journal of the American Geriatrics Society. 2021;69(SUPPL 1):S83. American Geriatrics Society Annual Meeting, AGS 2021. Virtual. No extractable data.
Golden RL, Mariani D, Carbonell E. The Age-Friendly Health Systems caregiver intervention: an evidence-based model for systemic change and improved outcomes. Journal of the American Geriatrics Society. 2022;70(SUPPL 1):S35. Annual Scientific Meeting of the American Geriatrics Society, AGS 2022. Orlando, FL United States. No extractable data.
Greenberg SA, Duffy EG, McCormack ME, A quality improvement approach to develop an educational initiative for an age-friendly health system. Geriatric Nursing. 2022;45:193–197. Education only.35512509
Lesser S, Zakharkin S, Louie C, Clinician knowledge and behaviors related to the 4Ms framework of Age-Friendly Health Systems. Journal of the American Geriatrics Society. 2022;70(3):789–800. No 4M implementation or not specific to 4Ms.34837381
Lundy J, Hayden D, Pyland S, An age-friendly health system. Journal of the American Geriatrics Society. 2021;69(3):806–812. Duplicate.33275785
Lynch MP, Kagan SH, Thomas TH, Analysis of Age-Friendly cancer care readiness. Oncology Nursing Forum. 2021;48(3):333–340. No 4M implementation or not specific to 4Ms.33856000
Nabong J, Evans E, Pohnert A, A quality improvement project to boost uptake of the Age-Friendly Health Systems 4Ms in convenient care clinics. Journal of the American Geriatrics Society. 2022;70(SUPPL 1):S178. Annual Scientific Meeting of the American Geriatrics Society, AGS 2022. Orlando, FL United States. Copublication or preliminary results of included study.
Ogunyemi AO, Balogun MR, Ojo AE, Barriers and facilitators to the delivery of Age-Friendly Health Services in primary health care centres in southwest, Nigeria: A qualitative study. PLoS ONE. 2024;19(3 MARCH):e0288574. No 4M implementation or not specific to 4Ms.38502650
Severance JJ, Rivera S, Cho J, A collaborative implementation strategy to increase falls prevention training using the Age-Friendly Health Systems approach. International Journal of Environmental Research and Public Health. 2022;19(10):5903. Wrong setting/Not outpatient.35627440
Sheber M, McKnight M, Liebzeit D, 335 "4Ms" conversation in the emergency department: A qualitative study. Annals of Emergency Medicine. 2022;80(4 Supplement):S143. ACEP Research Forum. Moscone Convention Center, San Francisco United States. Wrong setting/Not outpatient.
Shih C-I, Hung T-W, Chen W, Difficulties and countermeasures in implementing age-friendly policies in primary health centers in Taiwan. BMC Health Services Research. 2022;22(1):1–8. No 4M implementation or not specific to 4Ms.34974828
Shih CI, Hsu YH, Yang HF, Development of an age-friendly health service recognition framework for primary health centers in Taiwan. International Journal of Gerontology. 2021;15(1):58–63. No 4M implementation or not specific to 4Ms.
Smith E, Gasper WJ, Schneider PA, Room for improvement: Age-Friendly 4M assessments in a Veterans Affairs vascular surgery clinic. Journal of Vascular Surgery. 2022;75(6):e199–e200. VAM 2022. Boston United States. No 4M implementation or not specific to 4Ms.
Southerland LT, Presley CJ, Hunold KM, Barriers to and recommendations for integrating the age-friendly 4-Ms framework into electronic health records. Journal of the American Geriatrics Society. 2023;71(5):1573–1579. Wrong setting/Not outpatient.36455548
Tavares J, Santinha G, Rocha NP. Unlocking the WHO's age-friendly healthcare principles: Portugal's quest and recommendations. International Journal of Environmental Research and Public Health. 2023;20(22):7039. No 4M implementation or not specific to 4Ms.37998270
Taylor K, Wagner T. Age friendly emergency medicine services: integrating what matters, medications, mobility, and mentation into emergency response. Alzheimer's & Dementia : the journal of the Alzheimer's Association. 2022;18(Supplement 9):e061165. Wrong setting/Not outpatient.
Thombley RL, Rogers SE, Adler-Milstein J. Developing electronic health record-based measures of the 4Ms to support implementation and evidence generation for Age-Friendly Health Systems. Journal of the American Geriatrics Society. 2024;72(3):882–891. Wrong setting/Not outpatient.38126964
Vonnes C. Crafting age-friendly cancer care: A model for improvement utilizing the 4M’s framework across the continuum of an NCI designated cancer center. Journal of Geriatric Oncology. 2019;10(6 Supplement 1):S11–S12. 19th Conference of the International Society of Geriatric Oncology/SIOG 2019. Geneva Switzerland. Protocol.
Waters L, Marrs SA, Tompkins CJ, Creating interprofessional readiness to advance Age-Friendly U.S. Healthcare. International Journal of Environmental Research and Public Health. 2022;19(9):5258. Education only.35564650
Wismann A, Jelinek D, Hand R, Development of Age-Friendly Primary Care in an academic center. Journal of the American Geriatrics Society. 2023;71(Supplement 1):S89–S90. American Geriatrics Society Annual Meeting, AGS 2023. Long Beach, CA United States. Copublication or preliminary results of included study.
Yoo J, Choe I, Park J. Racial and ethnic disparity in 4M-based telehealth primary care and healthcare utilization in a provider shortage area. Journal of the American Geriatrics Society. 2023;71(Supplement 1):S90. American Geriatrics Society Annual Meeting, AGS 2023. Long Beach, CA United States. No 4M implementation or not specific to 4Ms.
Zuo JX, Szymanski EP, Fessler E, Implementation of a geriatric assessment SmartPhrase: A multi-institution pilot study. Journal of the American Geriatrics Society. 2023;71(Supplement 1):S150. American Geriatrics Society Annual Meeting, AGS 2023. Long Beach, CA United States. No 4M implementation or not specific to 4Ms.

Notes. 5 records were duplicated within this list.

Articles Whose Citations Were Searched
Bhattacharyya KK, Molinari V, Black K, Whitbourne SK. Creating age-friendly nursing homes: The time is now. Gerontol Geriatr Educ. 2023;44(4):613–630. doi:10.1080/02701960.2022.2106981 35950627
Church K, Munro S, Shaughnessy M, Clancy C. Age-Friendly Health Systems: Improving care for older adults in the Veterans Health Administration. Health Serv Res. 2023;58 Suppl 1(Suppl 1):5–8. doi:10.1111/1475-6773.14110
Hodge O, Rasekaba T, Blackberry I, Steer CB. Age-friendly healthcare: integrating the 4Ms to enable age-friendly cancer care. Curr Opin Support Palliat Care. 2024;18(1):9–15. doi:10.1097/SPC.0000000000000687 38252057
Liaw ST, Ansari S, Jonnagaddala J, Narasimhan P, Ashraf MM, Harris-Roxas B, Harris M. Use of mHealth for promoting healthy ageing and supporting delivery of age-friendly care services: a systematic review. International Journal of Integrated Care. 2019;19(4).
Liebzeit D, Krupp A, Bunch J, Rural age-friendly ecosystems for older adults: An international scoping review with recommendations to support age-friendly communities. Health Sci Rep. 2023;6(5):e1241. Published 2023 May 5. doi:10.1002/hsr2.1241 37152222
Lifset ET, Charles K, Farcas E, Ascertaining Whether an Intelligent Voice Assistant Can Meet Older Adults' Health-Related Needs in the Context of a Geriatrics 5Ms Framework. Gerontol Geriatr Med. 2023;9:23337214231201138. Published 2023 Sep 30. doi:10.1177/23337214231201138 37790195
Manning JM. The 4M Model. Crit Care Nurs Clin North Am. 2023;35(4):367–374. doi:10.1016/j.cnc.2023.06.003 37838412
Mate K, Fulmer T, Pelton L, Evidence for the 4Ms: Interactions and Outcomes across the Care Continuum. J Aging Health. 2021;33(7–8):469–481. doi:10.1177/0898264321991658 33555233
Montayre J, Foster J, Zhao IY, Age-friendly interventions in rural and remote areas: A scoping review. Australas J Ageing. 2022;41(4):490–500. doi:10.1111/ajag.13101 35796240
Raparla A, Thorngthip S, Pino L, Hughes R, Pohnert AM, Dolansky MA. Age-Friendly Health Systems: Delivering evidence-based care to older adults. Nursing. 2023;53(12):40–43. doi:10.1097/01.NURSE.0000991584.91771.17
Tavares J, Santinha G, Rocha NP. Age-Friendly Health Care: A Systematic Review. Healthcare (Basel). 2021;9(1):83. Published 2021 Jan 16. doi:10.3390/healthcare9010083 33561084
Winterton R, Hodgkin S, Clune SJ, Brasher K. Age-friendly care for older adults within rural Australian health systems: An integrative review. Australas J Ageing. 2021;40(1):16–34. doi:10.1111/ajag.12834 33739600
Zonsius MC, Myftari K, Newman M, Emery-Tiburcio EE. Optimizing Older Adults' Medication Use Nurses can partner with caregivers to promote safe medication administration. Home Healthcare Now. 2022;40(6):304–10.

Citations for Identified Conference Abstracts
Arany S, Medina-Walpole A, Caprio T. Pilot study of dental AFHS metrics based on a new 4Ms checklist. Journal of the American Geriatrics Society. 2023;71(Supplement 1):S150–S151. American Geriatrics Society Annual Meeting, AGS 2023. Long Beach, CA United States. doi:10.1111/jgs.18336
Carrico C, McKibbin C, Bennett K, ECHO in Action: Impact, Barriers, and Lessons Learned Across Six Age-Friendly Geriatric ECHOs. Journal of the American Geriatrics Society. 2022;70(SUPPL 1):S4. Annual Scientific Meeting of the American Geriatrics Society, AGS 2022. Orlando, FL United States. doi:10.1111/jgs.17755
Carvalho Do Amaral A, Hasnain M, Gruss V, Haque K. Implementation of Annual Wellness Visits as a tool to enhance patient-centered geriatric care in underserved communities. Journal of the American Geriatrics Society. 2023;71(Supplement 1):S173. American Geriatrics Society Annual Meeting, AGS 2023. Long Beach, CA United States. doi:10.1111/jgs.18336
Casey CM, Fox A, Leigh S, Caulley J, Hodges MO. Outcomes of a Geriatric Mini-Fellowship: An Age-Friendly 4M curriculum addresses the quadruple aim. Journal of the American Geriatrics Society. 2023;71(Supplement 1):S2–S3. American Geriatrics Society Annual Meeting, AGS 2023. Long Beach, CA United States. doi:10.1111/jgs.18336
Dobert R, Sibley A, Brennan M. Baystate health: An age friendly health system improving health outcomes for older adults (OA). Journal of the American Geriatrics Society. 2020;68(SUPPL 1):S277. Annual Scientific Meeting of the American Geriatrics Society, AGS 2020. Long Beach, CA United States. doi:10.1111/jgs.16431
Dobert R, Sibley A, Peretti J, Mustain C, Speight I, Brennan M. Maintaining 4m age friendly care standards in a house calls program, it takes a team! Journal of the American Geriatrics Society. 2021;69(SUPPL 1):S80–S81. American Geriatrics Society Annual Meeting, AGS 2021. Virtual. doi:10.1111/jgs.17115
Drost J, Fosnight S, Krebs A, Use of a high intensity clinic to implement the 4-M frame work in a community based health system. Journal of the American Geriatrics Society. 2020;68(SUPPL 1):S115–S116. Annual Scientific Meeting of the American Geriatrics Society, AGS 2020. Long Beach, CA United States. doi:10.1111/jgs.16431
Khanna P, Nemytova E, Ajmal S, Wallach AB, Chodosh J, Ouedraogo Tall S. Outcomes of 4Ms Assessments during Early Phase of Adoption at an Urban Safety Net Primary Care Geriatrics Clinic. Journal of the American Geriatrics Society. 2022;70(SUPPL 1):S46. Annual Scientific Meeting of the American Geriatrics Society, AGS 2022. Orlando, FL United States. doi:10.1111/jgs.17755
Kim L, Fadhel E, Chong MT, Racial/ethnic disparity in 4M-based primary care delivery via telehealth in provider shortage area. Journal of the American Geriatrics Society. 2022;70(SUPPL 1):S125. Annual Scientific Meeting of the American Geriatrics Society, AGS 2022. Orlando, FL United States. doi:10.1111/jgs.17755
O'Hara G, Parikh T, McIlvaine T, Lessons learned from implementing age-friendly care in a veterans affairs-based clinic and a safety-net hospital-based geriatrics primary care clinic. Journal of the American Geriatrics Society. 2021;69(SUPPL 1):S62. American Geriatrics Society Annual Meeting, AGS 2021. Virtual. doi:10.1111/jgs.17115
Rubino M, Waters L, Slattum P. An age friendly program to enhance primary care for an older population experiencing adverse social determinants of health. Journal of the American Geriatrics Society. 2021;69(SUPPL 1):S54. American Geriatrics Society Annual Meeting, AGS 2021. Virtual. doi:10.1111/jgs.17115
Vu KH, Cheung J, Diamond L, McPherson D, O'Hara G. Improving a Community-Based, Residency-Affiliated, Urban, Primary Care Clinic as an Age-Friendly Health System Utilizing the 4Ms Framework. Journal of the American Geriatrics Society. 2022;70(SUPPL 1):S253. Annual Scientific Meeting of the American Geriatrics Society, AGS 2022. Orlando, FL United States. doi:10.1111/jgs.v70.S1
Vu KH, Cheung J, McPherson D, Roh E, O'Hara G. Achieving Level 2 Age-Friendly Health Systems - Committed to Care Excellence Recognition as a Community-Based, Residency- Affiliated, Primary Care Clinic. Journal of the American Geriatrics Society. 2023;71(Supplement 1):S352. American Geriatrics Society Annual Meeting, AGS 2023. Long Beach, CA United States. doi:10.1111/jgs.18336
Yang HC, Kim L, Yoo J. Impact of Workforce Interprofessional Education and Telehealth Training on Care Plans and Financial Outcomes of Nevada Frail Older Adults (TH112B). Journal of Pain and Symptom Management. 2023;65(3):e255–e256. The Annual Assembly of Hospice and Palliative Care. Montreal Canada. doi:10.1016/j.jpainsymman.2022.12.037