# APPENDIX B SEARCH STRATEGIES

Search Date: 03/28/2024 | | Search Statement | Results
EMBASE | 1 | ((age or aged) adj1 friendly adj10 (care or healthcare or health service* or health system* or hospital*)).mp. [mp=title, abstract, heading word, drug trade name, original title, device manufacturer, drug manufacturer, device trade name, keyword heading word, floating subheading word, candidate term word] | 405
EMBASE | 2 | (4Ms or 5Ms or (‘What Matters’ and Medication and Mentation and Mobility)).mp. [mp=title, abstract, heading word, drug trade name, original title, device manufacturer, drug manufacturer, device trade name, keyword heading word, floating subheading word, candidate term word] | 1518
EMBASE | 3 | 1 or 2 | 1748
EMBASE | 4 | limit 3 to yr=“2015 -Current” | 1156
CINAHL | 1 | ((age or aged) N1 friendly N10 (care or healthcare or health service* or health system* or hospital*)) OR (4Ms or 5Ms (“What Matters” and Medication and Mentation and Mobility)); Limiters - Publication Date: 20150101-20241231 | 204
Ovid MEDLINE | 1 | ((age or aged) adj1 friendly adj10 (care or healthcare or health service* or health system* or hospital*)).mp. [mp=title, book title, abstract, original title, name of substance word, subject heading word, floating sub-heading word, keyword heading word, organism supplementary concept word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier, synonyms, population supplementary concept word, anatomy supplementary concept word] | 267
Ovid MEDLINE | 2 | (4Ms or 5Ms or (“What Matters” and Medication and Mentation and Mobility)).mp. [mp=title, book title, abstract, original title, name of substance word, subject heading word, floating sub-heading word, keyword heading word, organism supplementary concept word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier, synonyms, population supplementary concept word, anatomy supplementary concept word] | 580
Ovid MEDLINE | 3 | 1 or 2 | 766
Ovid MEDLINE | 4 | limit 3 to yr=“2015 -Current” | 534
Cochrane | 1 | (((“aged friendly” OR “age friendly”) NEAR/10 (healthcare OR “health care” OR hospital* OR health system* OR health service*)) OR “4Ms” OR “5Ms” OR (“What Matters” AND Medication AND Mentation AND Mobility)) in Title Abstract Keyword - (Word variations have been searched); Limit since 2015 | 72
Clinicaltrials.gov | 1 | ((“elder friendly” OR “elderly friendly” OR “senior friendly” OR “older friendly” OR “age friendly” OR “geriatric friendly”) OR “4Ms” OR “5Ms” OR (“What Matters” AND Medication AND Mentation AND Mobility)) | 11
| | Total | 1977
| | Total after deduplication | 1537