# APPENDIX A CONCEPTUAL MODEL

Appendix A shows the conceptual model of the relationship between contextual factors (barriers and facilitators), implementation support strategies, measures, and patient system factors. The first box focuses on the contextual factors (KQ1) and draws on the Consolidated Framework for Implementation Research 2.0. The first box has three concentric circles and next to this are two rectangles. The largest concentric circle is labeled as the Outer Setting domain with the example of “stakeholder partnerships” given. The next circle is labeled as the Inner Setting domain and provides the example of, “administrative support”. The third and smallest circle is labeled as the Individuals domain, and provides the example of, “lack of confidence in documentation.” The two rectangles connect to the Individuals domain and are Labeled as Implementation Process and Innovation domains. For the Implementation Process domain, the example of, “regular interaction between stakeholders,” is provided. For the Innovation domain, the figure indicates that none were identified. To the right of the box containing contextual factors, there is a bidirectional arrow leading to a box labeled implementation support strategies. This box contains a listing of the 9 Waltz clusters. To the right of the box containing the support strategies, there is an arrow pointing to a box focusing on Measure (KQ2A). Within this box, there are three smaller, stacked rectangles listing the AHRQ Health Care Quality Measures with arrows between them. The first rectangle is labeled as Structural and provides the example of, “Number of regions achieving IHI Regional Committed to care Excellence recognition.” The next rectangle is labeled as Process and provides the example, “Fall risk assessment screened for cognitive impairment.” The final rectangle is labeled as Outcome and provides the examples of, “FRAIL or SNAQ results.” Under these three boxes is an arrow leading from the contextual factors box directly to the measures box. There a rectangle coming off this arrow that is labeled as Patient and System Factors (KQ2B). For Patient factors, the examples of gender and race are provided. For System factors, rurality is provided as an example.