# ABBREVIATIONS TABLE

Abbreviation: Definition
ADL: Activities of daily living
ACP: Advance care planning
AFHS: Age-Friendly Health System
AHRQ: Agency for Healthcare Research and Quality
AHA: American Hospital Association
CHA: Catholic Health Association
CMS: Centers for Medicare and Medicaid Services
CASP: Critical Appraisal Checklists
DC: District of Columbia
EHR: Electronic health record
EMR: Electronic medical record
ERIC: Expert Recommendations for Implementing Change
FRAIL: Fatigue, Resistance, Ambulation, Illness, Loss of weight
FQHC: Federally qualified health centers
GRADE: Grading of Recommendations Assessment, Development and Evaluation
IRR: Incident rate ratio
IHI: Institute for Healthcare Improvement
KQ: Key questions
MD: Mean difference
NRCS: Non-randomized controlled studies
NR: Not reported
NP: Nurse Practitioner
GEC: Office of Geriatrics and Extended Care
GWEP: Geriatric Workforce Enhancement Program
PHQ2: Patient Health Questionnaire-2
PT: Physical therapy
PDSA: Plan-Do-Study-Act
RCT: Randomized controlled trial
RN: Registered nurse
RD: Risk difference
SNAQ: Simplified Nutrition Appetite Questionnaire
SARC-F: Strength, Assistance with walking, Rise from a chair, Climb stairs and Falls
SRDR+: Systematic Review Data Repository
TEP: Technical expert panel
TUG: Timed up and go test
VHA: Veterans Health Administration
4Ms: What Matters, Medication, Mentation, and Mobility