# SUMMARY AND DISCUSSION

## SUMMARY OF EVIDENCE BY KEY QUESTION

### Key Question 1 What is the effectiveness of EHR-based interventions in reducing unnecessary or inappropriate imaging?

### Key Question 2 Do EHR-based interventions vary in results by system?

Twenty-one studies provide moderate quality evidence that EHR-based interventions can reduce inappropriate test ordering by a moderate amount, and reduce overall utilization by a small amount. Low-quality evidence supports that interventions that include a “hard stop,” preventing ordering clinicians from overriding a decision support determination that a test is inappropriate, the use of audit-and-feedback as part of the implementation, and that are conducted in an integrated care delivery setting, are associated with greater effectiveness.

### Key Question 3

There are few data on the potential harms of decision support tools to reduce inappropriate radiology test ordering. Future studies should evaluate for harms – particularly investigating whether guidelines when applied in practice provide unanticipated results, or when there are issues related to workflow, efficiency, or provider dissatisfaction that could impact a decision support tool's effectiveness. For example, in a study of CDS to prevent drug-drug interactions, the use of a “hard stop” intervention – while effective in changing prescribing – resulted in delays in treatment for 4 patients, resulting in preventative stopping of the study by the Institutional Review Board.1 Another study, excluded from our review because it assessed a pediatric population, surveyed physicians and found that most felt the CDS was “a nuisance” and “not relevant to the complex or high risk patients they had to treat.”2 This highlights the need for assessment of harms and unintended effects in every evaluation.

## LIMITATIONS

### Publication Bias

The most important limitation to this review is the likely existence of publication bias. Although we did not detect any statistical evidence of publication bias, there surely must be more implementations of EHR-based interventions to improve appropriateness of radiology test ordering then the 22 published studies we found. Our expectation is that many such interventions are done and never formally evaluated or published. How the results of these implementations may differ from the published studies is unknown, but we expect both effective and ineffective implementations have likely occurred and not been published. This lack of publication is a major impediment toward more rapid learning of how health IT can best be implemented.

### Study Quality

In common with many other areas of health IT, we found key information on context and implementation to be lacking in published studies. For example, only one study reported on pilot testing of the intervention, and only about one-third of studies reported on clinician training as part of the implementation. This may perpetuate the belief that these kinds of health IT interventions can be developed separate from the workflow of practicing clinicians, and then simply “turned on” with the expectation that clinicians will know how to use the intervention and use it correctly. The dearth of reporting of possible harms is another key limitation. Every intervention has to be expected to potentially cause harms and these need to be explicitly measured.

### Heterogeneity

Heterogeneity in effectiveness is a prominent finding of our review. Our stratified analyses explained some of this heterogeneity, but the greater portion remains unexplained. It has been postulated that the majority of heterogeneity in health IT evaluations is due to details of the context and implementation that go unreported in published study. We expect the same to be true here. Heterogeneity is a primary contributor to low quality of evidence assessments.

### Applicability of Findings to the VA Population

Only 3 studies were performed in integrated care delivery settings, and only one study was performed in VA. However, there is evidence suggesting that interventions implemented in integrated care delivery settings may be more effective than in other settings, indicating VA may realize benefits equal to or greater than the average benefit reported here.

## RESEARCH GAPS/FUTURE RESEARCH

We identified the following research gaps:

Direct comparisons are needed of different intervention characteristics. We found suggestive evidence that interventions with a “hard stop” are more effective than other interventions, but to prove this hypothesis requires testing the 2 methods head-to-head in the same study. This should be easy to do, since randomization can occur at the provider level, and consist of the CDS with and without the hard stop.

More research is needed on possible harms. Harms of a CDS intervention with a “hard stop” have been reported in other clinical situations. An explicit assessment of harms should be incorporated into every study of interventions.

About half of our included studies collected data more than 7 years ago, and information technology and attitudes about the use of information technology change over time, so data from more recent time periods would be helpful.

One study reported differential effectiveness by target, and this should be assessed in future studies.

Like all health IT evaluations, more information about context and implementation is needed.

## CONCLUSIONS

Computerized decision support integrated with the electronic health record can reduce inappropriate use of diagnostic radiology testing by a moderate amount. The use of a “hard stop” as part of the intervention and use in an integrated care delivery setting may all increase effectiveness. There are few data on the potential harms of decision support tools to reduce inappropriate radiology test ordering. Future studies should evaluate for harms.