# RESULTS

## LITERATURE FLOW

From all sources, we retrieved 1,195 titles. From these, we identified 172 titles as being potentially relevant. After reviewing these 172 abstracts, we identified 105 titles for full text review. Of these, we rejected a total of 82 articles, with 10 rejected for their study design (eg, a commentary, editorial, review, etc), 27 rejected as being about radiology imaging for screening, one rejected for being in a child-aged population, and 39 rejected as not being EHR-based or not about CDS or not about imaging (see Figure 1 for literature flow details).

Figure 1 Literature Flow Chart

* Results from prior systematic reviews (N=152), the existing database (N=226), the update searches (N=793), and articles identified during reference mining (N=24) were deduplicated to reach this number.

** Manuscript reference list includes additional references cited for background and methods plus websites relevant to key questions.

Of the 23 articles included, 3 were randomized trials,16-18 7 were time series studies,19-25 and 13 were pre-post studies.26-38 Seven studies collected data prior to the year 2000,^16-18,20,21,27,36^ and 7 studies included data collection within the past 5 years (2009 or later).19,22,29-31,33,38 Ten interventions targeted what was sometimes called “high cost imaging,” which usually included CT and MRI and occasionally nuclear medicine tests as well.16,19,22,24,25,31,33-35,37,38 Four interventions targeted pulmonary CT angiography,23,28,32,38 Two studies targeted chest x-ray,17,30 4 interventions targeted multiple radiologic investigations,20,26,29,36 and 3 studies had other radiologic targets.18,21,27

Studies were mostly single institution implementations, and at US academic medical centers. Thirteen studies, or just over half of all studies, were from the “HIT leaders,” meaning US academic centers who have a long history of development, implementation, evaluation, and publication of health IT.16-18,22-25,31,33,36-38 Ten of these studies (35%) came from institutions affiliated with Harvard.16,18,22-25,31,33,37,38 Three studies came from integrated healthcare delivery organizations, in particular Kaiser,21 VA,32 and Virginia Mason.19

In 5 studies, the intervention consisted of simply the display of information, such as the cost of tests, relevant guidelines, or an appropriateness rating for the requested radiology examination for that indication.16,17,21,29,36 Nine studies displayed patient-specific information about whether or not the requested study was consistent with existing guidelines (or something similar).18,23,25,27,28,30,31,35,38 Four studies included what we characterized as a “soft stop,” meaning for radiology orders that the CDS rated as inconsistent with guidelines or inappropriate, the provider needed to enter a reason why the CDS advice was being over-ridden.20,24,26,34 Five studies included a “hard stop,” meaning providers were prevented from ordering radiology examinations the CDS classified as inappropriate without getting approval from some external person, usually a radiologist or senior clinician.19,22,32,33,37

Almost all interventions were integrated with CPOE, gave real-time feedback, and a recommended course of action. Only one study specifically indicated that the intervention was developed iteratively or pilot tested,18 about one-third of studies reported clinician training was part of the implementation process,19,23,26-28 5 studies reported including audit-and-feedback as part of the implementation,19,22,24,26,33 and 7 studies reported on other implementation characteristics, barriers, and facilitators (including having a culture of evidence-based medicine, a phased implementation, salaried physicians, and a risk contract with the payor of care).19,22,25,26,28,33,35 The Evidence Tables present details of all 23 included studies (see Appendix A).

Two studies did not present data sufficient to include in our quantitative analysis, one because it did not present comparative data without the intervention26 and one because the outcome was an aggregate measure of many tests, and data specific to the radiology targets were not presented.36 Of the remaining 21 studies, 13 reported an appropriateness outcome and 13 reported a utilization outcome, while 5 studies reported both. See Table 2 for which outcomes were reported in which studies.

Table 2 Articles with Type of Outcome Presented

Author, Year | Appropriateness | Utilization
Bates, 1997^16^ | | X
Blackmore, 2011^19^ | | X
Carton, 2002^20^ | X
Chin, 1999^21^ | X | X
Day, 1995^27^ | X | X
Dresher, 2011^28^ | X
Durand, 2013^29^ | | X
Flamm, 2013^30^ | X
Gupta, 2014^31^ | X
Harpole, 1997^18^ | | X
Ip, 2014^33^ | X | X
Ip, 2013^22^ | | X
Raja, 2012^23^ | X | X
Raja, 2014^38^ | X | X
Rosenthal, 2006^24^ | X
Sanders, 2001^34^ | | X
Sistrom, 2009^25^ | | X
Solberg, 2010^35^ | X
Soo Hoo, 2011^32^ | X
Tierney, 1988^17^ | | X
Vartanians, 2010^37^ | X

Figure 2 presents the results from the 5 studies reporting both appropriateness and utilization outcomes. While the 2 outcomes are directionally consistent within study, in 3 studies the effect size for appropriateness was much greater than for utilization. In general, this is to be expected. Most radiology examinations are not ordered for inappropriate reasons, and thus an intervention targeted at reducing inappropriate test ordering will have a larger effect on appropriateness than it will on utilization. For example, if a particular radiological procedure is ordered appropriately 70% of the time and inappropriately 30% of the time among 100 consecutive orders, then an intervention that successfully reduces inappropriate use by 50% will result in only 15 inappropriate test orders, while utilization will decrease only 15% (from 100 test orders to 85 test orders, the latter consisting of 70 appropriate orders and 15 inappropriate orders). Thus, we expect that utilization will be less affected than appropriateness for these interventions. The study by Raja and colleagues published in 2014 reported both at an appropriateness outcome, as in the proportion of radiologic tests ordered that met a national standard and the patient positive yield of radiologic examinations. We included both here for comparison.

Figure 2 Studies Reporting Both Appropriateness and Utilization Outcomes

ES=effect size, CI=confidence interval

## KEY QUESTION 1 What is the effectiveness of EHR-based interventions in reducing unnecessary or inappropriate imaging?

## KEY QUESTION 2 Do EHR-based interventions vary in results by system?

We combine our presentation of results for these 2 key questions, since they are interrelated.

Thirteen studies contributed to each pooled analysis, one pooled analysis for appropriateness and one pooled analysis for utilization. Five studies contributed data to both. Our primary outcome was the effect on appropriateness.

Figure 3 displays the results for individual studies reporting appropriateness. Nine of the 13 studies reported statistically significant benefits of the intervention, 2 reported a benefit that was not statistically significant, and 2 studies reported no effect. The random effects pooled estimate from all 13 studies was an effect size of 0.48 (95% CI: -0.71, -0.25). This equates to a “moderate” sized effect, according to a conventional classification.39 Substantial heterogeneity is present, as indicated by the I^2^ statistic of 99.5%, and the visual inspection of the plot. Neither Begg's nor Egger's test indicated the presence of publication bias (p=0.951, p=0.339, respectively). A sensitivity analysis that included the appropriateness outcome instead of the yield outcome for Raja (2014) yielded little difference in the pooled estimate (0.52, 95% CI -0.73, -0.31).38

Figure 3 Results for Appropriateness from Individual Studies

As a clinical example of what constitutes a moderate-sized effect, consider the results of the study by Gupta and colleagues, which reported an effect size of 0.67 associated with implementation of the CDS intervention. In clinical terms, this meant that before CDS implementation the percentage of head CT examinations ordered for appropriate reasons in the ER for patients with mild traumatic brain injury was 49%. After implementation of the CDS, this rate increased to 76.5%.31 As a second example, the study by Rosenthal and colleagues reported an effect size of 0.63 associated with implementation of a CDS, giving appropriateness scores for a number of radiologic procedures. Before the intervention, 6% of procedures were judged as being of low utility; after the intervention this value dropped to 2%.24

Figure 4 displays the results for the 13 studies reporting utilization outcomes. Six studies reported statistically significant benefits of the intervention, and 7 studies reported essentially no effect. The random effects pooled estimate from all 13 studies was an effect size of 0.13 (95% CI: -0.23, -0.04). This equates to a “small” sized effect, according to a conventional classification. Despite a narrower range of effect sizes in these 13 studies (10 of the 13 studies cluster between zero and an effect size of 0.21) compared to the range of effect sizes for the appropriateness outcomes, like the appropriateness studies substantial heterogeneity is present, as indicated by the I2 statistic of 100%. Neither Begg's nor Egger's test indicated the presence of publication bias (p=0.392, p=0.259, respectively).

Figure 4 Results for Utilization from Individual Studies

### Effect of Intervention Characteristics, Setting, Implementation, and Target on Effectiveness

We explored 4 hypotheses regarding effectiveness, one each for characteristics of the intervention, the setting (integrated care delivery versus other settings), the implementation process (the use of audit and feedback was the only implementation characteristic with sufficient data to support a stratified analysis), and the radiologic target of the intervention. We had insufficient studies to support robust pooled estimates of individual strata or to support multivariable analyses. Furthermore, since appropriateness was our primary outcome we present stratified results only for this outcome. Nevertheless, some patterns are apparent.

Figure 5 presents the results of the appropriateness outcomes, stratified by intervention characteristics and settings. “A” interventions provided information only; in the included study it presented internally developed guidelines any time an upper GI series order was placed.21 “B” interventions presented information on appropriateness or guidelines specifically tailored to the individual patient, often as a pop-up or alert. Some of these interventions also recommended alternative interventions, but did not include any barrier for the clinician to order the test. “C” interventions in general were similar to “B” interventions, but required the ordering clinician to justify with free text why they were overriding the decision support recommendation that a study was inappropriate. We called this a “soft stop.” “D” interventions included what we called a “hard stop,” meaning the intervention prevented the clinician from ordering a test contrary to the CDS determination of inappropriateness, until additional discussion with or permission obtained from another clinician or radiologist.

Figure 5 Appropriateness Results Stratified by Intervention Characteristics and by Setting

All of the “D” studies reported moderate-to-large effects on appropriateness, while the “B” and the “C” studies reported more variable and generally lesser effects. The one “A” study, by Chin and colleagues,21 reported a large effect. This study displayed locally developed guidelines for appropriate upper gastro intestinal (UGI) ordering at the time an order was placed. This study was conducted in an integrated care delivery setting with a high baseline rate of inappropriate use (45%), which may partly explain these strikingly successful findings.

Regarding setting, the 2 studies conducted in integrated care settings all reported large effects on appropriateness. Studies conducted in other settings found much smaller effects, while studies at 10 US institutions that are leaders in health IT reported heterogeneous results, although 4 of the 6 studies of appropriateness at the health IT leaders reported statistically significant benefits of the intervention.

Figure 6 presents the results of the appropriateness, respectively, stratified by whether or not the publication reported that audit-and-feedback was part of the implementation process and by the target of the intervention. There did not seem to be clear patterns, although both studies using audit-and-feedback reported moderate-to-large effects. In the study by Rosenthal and colleagues, “physicians, who [ordered] more than a few examinations with low utility scores [were] contacted by one of their senior clinical leaders and counseled about appropriate ordering.”24 In the study by Ip and colleagues, audit-and-feedback was accomplished by sending to primary care providers quarterly practice pattern variation reports depicting the number of back MRIs ordered per the number of low back pain related visits.33

Figure 6 Appropriateness Results Stratified by Implementation Characteristics and by Target

No pattern of differential effectiveness is as clearly apparent as in the preceding figures, although in a study of one intervention a statistically significant effect was seen for CT scans and nuclear radiology tests but not MRI,22 suggesting the possibility of a differential effect of interventions based on their target.

Two studies which otherwise met our inclusion criteria could not be included in the pooled analysis because they did not present sufficient data. In one study a rural family medicine clinic in Canada made computerized decision support available to any interested physician. The majority of physicians were infrequent users of the system, which was voluntary. Among 904 diagnostic imaging studies ordered using the system, clinical guidelines applied to 58%. Of these, 29% were identified as inappropriate and an alternative diagnostic strategy suggested. Of these, physicians followed the suggestion in 25% of cases. This study could not be included in our pooled analysis because it did not present data from the pre-intervention period.26 The second study was a time series study of displaying the costs for a large number of outpatient diagnostic tests (urinalysis, complete blood count, serum electrolytes, etc).36 Three radiologic tests relevant to this review were included: chest x-ray, head CT scan, and head MRI. This study could not be included in our pooled analysis because it did not report results separately for the individual tests. The effect of the intervention on the aggregate of all these diagnostic tests was a statistically significant 14% reduction in utilization. This significant finding is in contrast to 3 other studies of an intervention that presented cost data, all of which reported no effect on utilization.

### VA Studies

We identified one study conducted in a VA setting.32 This was a single site, pre-post study at an urban, academically affiliated VA. Locally developed guidelines were developed for the appropriate use of CT angiography for suspected pulonary embolus. These were then incorporated in the CPOE fuction of the VA electronic health record (CPRS version 1.0.27). The order entry menu screen included the Wells criteria point score. The ordering physician was required to complete the checklist to generate a Wells score. If the score was 4 or less, the physician was required to get a D-dimer test. If the D-dimer test was above a certain threshold, the order was allowed to proceed without any additional barriers. If the D-dimer was below that threshold, the ordering physician was required to consult with the on-call chest radiology attending for approval (a “hard stop”). In the 2 years prior to the intevention, the yield of positive CT angiography studies was 3.1%. This increased to 16.5% after inplementation of the intervention. There was no assessment of possible patient harms or physician reactions to the use of the intervention.

### Summary of Findings and Quality of Evidence for Key Question 1 and 2

Twenty-one studies provide moderate quality evidence that EHR-based interventions can reduce inappropriate test ordering by a moderate amount, and reduce overall utilization by a small amount. Low quality evidence supports that interventions that include a “hard stop,” preventing ordering clinicians from overriding a decision support determination that a test is inappropriate, and implementation in an integrated care delivery setting, are associated with greater effectiveness. Audit-and-feedback may be a useful implementation tool, but data are too sparse to draw conclusions. We judged the quality of evidence regarding appropriateness and utilization as moderate, due to heterogeneity in the results. We judged the quality of evidence regarding the characteristics as low, due to the sparseness of the data and indirect nature of the comparisons. That is, these characteristics have not been tested as a priori hypotheses for differential effectiveness within the same study.

## KEY QUESTION 3 What are the harms or potential harms associated with EHR-based interventions used to reduce inappropriate imaging?

Four studies reported on harms associated with their interventions.18,26,28,30 One study evaluating a decision support tool to reduce unnecessary pre-operative testing found that with the intervention there was an increase in the percent of pre-operative chest x-rays inappropriately not ordered.30 Prior to the intervention 1.9% of patients did not get a chest x-ray when indicated compared to 9.3% after the intervention. The clinical impact of this is not known. Another study of a decision support tool to reduce abdominal kidney, ureter, bladder (KUB) x-rays identified 12 KUB studies out of a total of 255 performed against the advice of the tool where there were positive findings.18 Of these 12, six KUB studies were felt to have significantly influenced patient outcomes, making it unclear whether following the locally developed guidance could have endangered the patient. The 2 other studies reported on qualitative information from physician surveys which primarily identified lack of interest in using the decision support tools because of time constraints and perceived inefficiencies.26,28

### Summary of Findings

There are few data on the potential harms of decision support tools to reduce inappropriate radiology test ordering. Future studies should evaluate for harms – particularly investigating whether guidelines when applied in practice provide unanticipated results, or when there are issues related to workflow, efficiency, or provider dissatisfaction that could impact a decision support tool's effectiveness. For example in a study of CDS to prevent drug-drug interactions, the use of a “hard stop” intervention – while effective in changing prescribing – resulted in delays in treatment for 4 patients, resulting in preventative stopping of the study by the Institutional Review Board.1 Another study, excluded from our review because it assessed a pediatric population, surveyed physicians and found that most felt the CDS was “a nuisance” and “not relevant to the complex or high risk patients they had to treat.”2 This highlights the need for assessment of harms and unintended effects in every evaluation.

### Quality of Evidence for Key Question 3

We judged the quality of evidence for harms as very low, meaning any estimate is uncertain.