# REFERENCES

1 Strom BL, Schinnar R, Aberra F, et al. Unintended effects of a computerized physician order entry nearly hard-stop alert to prevent a drug interaction: a randomized controlled trial. Archives of Internal Medicine. 2010;170(17):1578-1583. [pmid: 20876410].
2 Bowen S, Johnson K, Reed MH, Zhang LP, Curry L. The Effect Of Incorporating Guidelines Into a Computerized Order Entry System for Diagnostic Imaging. Journal of the American College of Radiology. Apr. 2011;8(4):251-258. [pmid: 21458763].
3 Kocher KE, Meurer WJ, Fazel R, Scott PA, Krumholz HM, Nallamothu BK. National trends in use of computed tomography in the emergency department. Ann. Emerg. Med. 2011;58(5):452-462. e453. [pmid: 21835499].
4 Korley FK, Pham JC, Kirsch TD. Use of advanced radiology during visits to US emergency departments for injury-related conditions, 1998-2007. JAMA. 2010;304(13):1465-1471. [pmid: 20924012].
5 Chou R, Fu R, Carrino JA, Deyo RA. Imaging strategies for low-back pain: systematic review and meta-analysis. The Lancet. 2009;373(9662):463-472.
6 Cassel CK, Guest JA. Choosing wisely: helping physicians and patients make smart decisions about their care. JAMA. 2012;307(17):1801-1802. [pmid: 22492759].
7 Chaudhry B, Wang J, Wu S, et al. Systematic review: impact of health information technology on quality, efficiency, and costs of medical care. Ann Intern Med. May. 16. 2006;144(10):742-752. [pmid: 16702590].
8 Buntin MB, Burke MF, Hoaglin MC, Blumenthal D. The benefits of health information technology: a review of the recent literature shows predominantly positive results. Health Affairs. 2011;30(3):464-471. [pmid: 21383365].
9 Goldzweig C, Orshansky G, Paige N, et al. Electronic patient portals: evidence on health outcomes, satisfaction, efficiency, and attitudes: a systematic review. Annals of Internal Medicine. 2013;159(10):677. [pmid: 24247673].
10 Jones SS, Rudin RS, Perry T, Shekelle PG. Health information technology: an updated systematic review with a focus on meaningful use. Annals of Internal Medicine. 2014;160(1):48-54. [pmid: 24573664].
11 Georgiou A, Prgomet M, Markewycz A, Adams E, Westbrook JI. The impact of computerized provider order entry systems on medical-imaging services: a systematic review. Journal of the American Medical Informatics Association. 2011;18(3):335-340. [pmid: 21385821].
12 Roshanov PS, Misra S, Gerstein HC, et al. Computerized clinical decision support systems for chronic disease management: a decision-maker-researcher partnership systematic review. Implement Sci. 2011;6(1):92. [pmid: 21824386].
13 Fillmore CL, Bray BE, Kawamoto K. Systematic review of clinical decision support interventions with potential for inpatient cost reduction. BMC Med. Inform. Decis. Mak. Dec. 2013:13. [pmid: 23347433].
14 Borenstein M, Hedges LV, Higgins JP, Rothstein HR. Chapter 7. Introduction to meta-analysis. John Wiley & Sons. 2011.
15 Grading of Recommendations Assessment DaEGWG. GRADE working group. 2013. http://www.gradeworkinggroup.org/index.htm. 9/5/2014.
16 Bates DW, Kuperman GJ, Jha A, et al. Does the computerized display of charges affect inpatient ancillary test utilization?. Arch Intern Med. Nov. 24. 1997;157(21):2501-2508. [pmid: 9385303].
17 Tierney WM, McDonald CJ, Hui SL, Martin DK. Computer predictions of abnormal test results: effects on outpatient testing. JAMA. 1988;259(8):1194-1198. [pmid: 3339821].
18 Harpole LH, Khorasani R, Fiskio J, Kuperman GJ, Bates DW. Automated evidence-based critiquing of orders for abdominal radiographs: impact on utilization and appropriateness. J Am Med Inform Assoc. Nov-Dec. 1997;4(6):511-521. [pmid: 9391938].
19 Blackmore CC, Mecklenburg RS, Kaplan GS. Effectiveness of clinical decision support in controlling inappropriate imaging. J Am Coll Radiol. Jan. 2011;8(1):19-25. [pmid: 21211760].
20 Carton M, Auvert B, Guerini H, et al. Assessment of radiological referral practice and effect of computer-based guidelines on radiological requests in two emergency departments. Clinical radiology. 2002;57(2):123-128. [pmid: 11977945].
21 Chin HL, Wallace P. Embedding guidelines into direct physician order entry: simple methods, powerful results. Paper presented at: Proceedings of the AMIA Symposium. 1999.
22 Ip IK, Schneider L, Seltzer S, et al. Impact of provider-led, technology-enabled radiology management program on imaging. Am J Med. Aug. 2013;126(8):687-692. [pmid: 23786668].
23 Raja AS, Ip IK, Prevedello LM, et al. Effect of computerized clinical decision support on the use and yield of CT pulmonary angiography in the emergency department. Radiology. Feb. 2012;262(2):468-474. [pmid: 22187633].
24 Rosenthal DI, Weilburg JB, Schultz T, et al. Radiology order entry with decision support: initial clinical experience. Journal of the American College of Radiology. 2006;3(10):799-806. [pmid: 17412171].
25 Sistrom CL, Dang PA, Weilburg JB, Dreyer KJ, Rosenthal DI, Thrall JH. Effect of Computerized Order Entry with Integrated Decision Support on the Growth of Outpatient Procedure Volumes: Seven-year Time Series Analysis 1. Radiology. 2009;251(1):147-155. [pmid: 19221058].
26 Curry L, Reed MH. Electronic decision support for diagnostic imaging in a primary care setting. Journal of the American Medical Informatics Association. May. 2011;18(3):267-270. [pmid: 21486884].
27 Day F, Hoang LP, Ouk S, Nagda S, Schriger DL. The impact of a guideline-driven computer charting system on the emergency care of patients with acute low back pain. Proc Annu Symp Comput Appl Med Care. 1995:576-580. [pmid: 8563351].
28 Drescher FS, Chandrika S, Weir ID, et al. Effectiveness and acceptability of a computerized decision support system using modified Wells criteria for evaluation of suspected pulmonary embolism. Ann. Emerg. Med. 2011;57(6):613-621. [pmid: 21050624].
29 Durand DJ, Feldman LS, Lewin JS, Brotman DJ. Provider Cost Transparency Alone Has No Impact on Inpatient Imaging Utilization. Journal of the American College of Radiology. Feb. 2013;10(2):108-113. [pmid: 23273974].
30 Flamm M, Fritsch G, Hysek M, et al. Quality improvement in preoperative assessment by implementation of an electronic decision support tool. J Am Med Inform Assoc. Jun. 2013;20(e1):e91-96. [pmid: 23599223].
31 Gupta A, Ip IK, Raja AS, Andruchow JE, Sodickson A, Khorasani R. Effect of clinical decision support on documented guideline adherence for head CT in emergency department patients with mild traumatic brain injury. J Am Med Inform Assoc. Feb. 17. 2014.
32 Hoo GW, Wu CC, Vazirani S, Li Z, Barack BM. Does a clinical decision rule using D-dimer level improve the yield of pulmonary CT angiography?. AJR Am J Roentgenol. May. 2011;196(5):1059-1064. [pmid: 21512071].
33 Ip IK, Gershanik EF, Schneider LI, et al. Impact of IT-Enabled Intervention on MRI Use for Back Pain. Am J Med. Feb. 7. 2014.
34 Sanders DL, Miller RA. The effects on clinician ordering patterns of a computerized decision support system for neuroradiology imaging studies. Proc AMIA Symp. 2001:583-587. [pmid: 11825254].
35 Solberg LI, Wei F, Butler JC, Palattao KJ, Vinz CA, Marshall MA. Effects of electronic decision support on high-tech diagnostic imaging orders and patients. Am J Manag Care. Feb. 2010;16(2):102-106. [pmid: 20148614].
36 Tierney WM, Miller ME, McDonald CJ. The effect on test ordering of informing physicians of the charges for outpatient diagnostic tests. N Engl J Med. May. 24. 1990;322(21):1499-1504. [pmid: 2186274].
37 Vartanians VM, Sistrom CL, Weilburg JB, Rosenthal DI, Thrall JH. Increasing the Appropriateness of Outpatient Imaging: Effects of a Barrier to Ordering Low-Yield Examinations 1. Radiology. 2010;255(3):842-849. [pmid: 20501721].
38 Raja AS, Gupta A, Ip IK, Mills AM, Khorasani R. The use of decision support to measure documented adherence to a national imaging quality measure. Acad Radiol. Mar. 2014;21(3):378-383. [pmid: 24507424].
39 Cohen J. Statistical Power Analysis for the Behavioral Sciences. 2nd ed. Hillsdale, NJ. Lawrence Erlbaum Assoc, Inc. 1988.