# METHODS

## TOPIC DEVELOPMENT

This report was developed based on a nomination from the VHA Choosing Wisely Workgroup, including Dr. David Atkins, Director of Health Services Research and Development, Dr. Charles Anderson, Chief Consultant for Diagnostic Services, and Sherrill Snuggs, Utilization Officer in the Office of Patient Care Services, in an effort to implement some of the segments of the “Choosing Wisely” campaign. In 2011, the American Board of Internal Medicine, working with Consumer Reports, organized the “Choosing Wisely” campaign in conjunction with 9 other leading medical professional groups, including the American College of Physicians, the leading medical organization dealing with adult medical care and highly relevant to Veterans' care.6 These organizations were asked to identify 5 tests or treatments that in their professional opinions, based on published guidelines, were often used inappropriately. Leading this list were several imaging studies including studies such as stress cardiac imaging in asymptomatic patients, routine preoperative chest x-rays in asymptomatic patients, and routine imaging in the absence of “red flag symptoms” for low back pain.

In recognition of the risks and costs associated with inappropriate imaging, VA leadership has requested an evidence synthesis which evaluates studied methods for reducing inappropriate imaging that center around the EHR.

The final key questions are:

Key Question 1: What is the effectiveness of EHR-based interventions in reducing unnecessary or inappropriate imaging?

Key Question 2: Do EHR-based interventions vary in results by system?

Key Question 3: What are the harms or potential harms associated with EHR-based interventions used to reduce inappropriate imaging?

The PROSPERO registration number is CRD42014009557.

## SEARCH STRATEGY

Our search strategy had 4 components:

The primary component was a search of an existing database developed from 4 prior, broad-based reviews of health information technology (IT).7-10 These 4 reviews were done using similar search strategies (covering the period 1995-2013) and inclusion/exclusion criteria, and were designed to identify all published hypothesis-testing studies of clinical health IT. Hypothesis-testing studies included randomized trials, controlled before-and-after studies, time series studies, and pre-post studies. These studies were further classified according to the health IT functionality, including clinical decision support (CDS), computerized provider order entry, patient care reminders, e-prescribing, health information exchange, etcetera. In the most recent review, summary data were presented which showed that of 1057 health IT studies in the database, 417 were classified as CDS. These 417 titles and abstracts were searched for studies eligible for this review (eg, CDS aimed at reducing inappropriate radiology use).

The second component of our search was reference mining of 3 potentially relevant systematic reviews:

1. The impact of computerized provider order entry systems on medical imaging services: a systematic review.11
  This review included 8 studies classified as ordering of medical imaging examinations by the provider.
2. Computerized clinical decision support systems for chronic disease management: a decision-maker-researcher partnership systematic review.12
  This review included 36 studies. It also contained a list of criteria for characterizing CDS systems that included whether it was integrated with the electronic health record (EHR) or computerized physician order entry (CPOE), whether the CDS was automated through the EHR, whether it was pilot tested, whether it gave feedback at the time of care, whether the CDS suggested procedures, and whether the authors of the article were also the developers of the CDS. We adapted this list for our own use.
3. Systematic review of clinical decision support interventions with potential for inpatient cost reduction.13
  This review identified 3 studies of radiology interventions.

Our third component was a targeted search of PubMed from 2011 to 9/10/2014, looking specifically at decision support for imaging, along with 2 searches constructed to identify articles related to 2 key references in Web of Science and PubMed (see Appendix B for this search strategy).

Our fourth component was to reference mine all included articles.

## STUDY SELECTION

All reference titles and abstracts were screened in duplicate. If either reviewer selected a title or abstract, it was included for further review. Full text articles were then reviewed in duplicate, with all discrepancies discussed with the group. References were selected based on the following inclusion criteria:

Participants: Adult population. Studies aimed only at children were excluded. Studies with mixed populations were included.

Intervention: EHR-based interventions for reducing imaging for diagnostic purposes (as opposed to screening) considered inappropriate or unnecessary based on clinical guidelines. This meant that studies seeking to increase the use of radiographic imaging like mammography for breast cancer screening were excluded. Studies of systems running on personal digital assistants were excluded. Studies of web-based interventions or computerized, stand-alone systems that we judged could be easily incorporated into the EHR were included.

Comparator (study design): Usual care.

Outcome: Rates of imaging procedures judged as unnecessary based on existing clinical guidelines. Studies that reported on changes in appropriateness (as opposed to decrease in appropriateness) were also included. Studies that targeted the use of imaging procedures stated as being overused and then reporting only utilization data were included. Utilization outcomes were considered separate from appropriateness outcomes. A table of all outcomes included as “appropriateness” is in Appendix C.

Timing: All times.

Setting: Ambulatory, hospital, and emergency department settings.

## DATA ABSTRACTION

Data were extracted by 2 reviewers, and discrepancies were reconciled with the group. Articles had data abstracted on study design, time period, setting, imaging modality, intervention, comparison, sample size, target of intervention, findings, IT design, data entry for intervention, and implementation characteristics. See Appendix D for the full list of data abstracted from each article.

## QUALITY ASSESSMENT

We assessed the quality of studies by their design and the degree to which they reported information about intervention and implementation characteristics (see Table 1).

Table 1 Criteria Used to Assess the Quality of Included Studies

IT Design
Is it integrated with CPOE?
Does it give real time feedback at point of care?
Does the CDS suggest a recommended course of action?
Intervention Classification
Data Entry Source
Is it automated through EHR (eg, only uses data already being entered for clinical care)?
Does clinical staff enter data specifically for intervention?
Implementation Characteristics
Was it pilot tested or used an iterative process of development/implementation?
Was there any user training/clinician education?
Are the authors also the developers and part of the user group for the CDS?
Was there use of audit-and-feedback (or other internal incentive)?
Are there any other implementation components not already discussed?

## DATA SYNTHESIS

We constructed evidence tables showing the study characteristics and results for all included studies. We used as the primary outcome the effect of the intervention on the appropriateness outcome. As a secondary outcome, we used the effect on the utilization. For studies presenting count data or for which a count could be calculated (from a percentage), an odds ratio and associated standard error were calculated. For comparability, the log odds ratios and their standard errors were converted into Cohen's d effect sizes.14 For studies presenting means and measures of variation, Cohen's d effect sizes were calculated directly. For each study, we used the difference between the pre-intervention period and the post-intervention period, or the difference between the time series projection of performance in the absence of the intervention compared to actual performance during the intervention, or the difference between providers randomized to the intervention or control, as appropriate to the study design and the available data. Results were converted to effect sizes for the analysis. Random effects meta-analyses were conducted using the H-K variance estimator.

After collecting data on the interventions, implementations, and settings but prior to extraction of outcomes data, we developed 4 hypotheses regarding effectiveness of the intervention, one in each category of intervention characteristics, settings, implementation, and target:

1. Interventions will vary in their effectiveness according to the following rank order: (a) interventions that present only information, (b) interventions that include a pop-up or reminder that the selected radiographic examination does not meet current guidelines, (c) interventions that require an active override for providers to continue to order a radiographic examination not supported by guidelines (ie, “soft stop”), or (d) interventions that forbid providers from ordering a radiographic examination not supported by guidelines unless/until consultation with a peer or expert (ie, “hard stop”).
2. Interventions will be more effective in settings that are integrated networks of care (eg, VA, Kaiser) than in other settings.
3. Interventions will be more effective if they include other implementation components, such as audit and feedback, academic detailing, etcetera.
4. Interventions may vary by the radiographic modality they target.

## RATING THE BODY OF EVIDENCE

The evidence was assessed using the Grading of Recommendations Assessment, Development and Evaluation (GRADE) criteria, which uses the domains of study design limitations, inconsistency, indirectness, and imprecision in results.15 The GRADE Working Group classified the quality of evidence across outcomes according to the following criteria:

- High = Further research is very unlikely to change our confidence on the estimate of effect.
- Moderate = Further research is likely to have an important impact on our confidence in the estimate of effect and may change the estimate.
- Low = Further research is very likely to have an important impact on our confidence in the estimate of effect and is likely to change the estimate.
- Very Low = Any estimate of effect is very uncertain.

## PEER REVIEW

A draft version of this report was reviewed by 2 technical experts and 2 members of VA clinical leadership. Reviewer comments were addressed and our responses were incorporated into the final report. The complete set of comments and responses can be found in Appendix E.