# INTRODUCTION

There are widespread concerns within Veterans Affairs (VA) healthcare and in non-VA US healthcare that the costs of healthcare are rising at unsustainable rates. One driver of cost is the increasing use of radiology imaging procedures, particularly advanced imaging techniques such as computed tomography (CT) scanning, magnetic resonance imaging (MRI), and CT angiography. Advances in imaging capabilities allow physicians to image ever-finer areas within the body, and the ease with which many of these tests are ordered has led to dramatic increases in the rates of use of many tests. For example, the use of CT scans in the Emergency Department (ED) grew by 330% in the 12 years from 1996 through 2007, at a time when the rate of ED visits grew by only 11%.3 Similarly, other investigators reported a 3-fold increase in the likelihood of getting a CT scan or MRI during an ED visit between 1998 and 2007.^4^

These dramatic increases in utilization have led to increased scrutiny regarding the clinical value of these imaging studies. In some cases, strong evidence exists that the imaging studies provide no value, or even harm patients. For example, a meta-analysis of early lumbar imaging for patients with acute low back pain included 5 randomized controlled trials (RCTs) where patients were randomized to receive or not receive early imaging in the form of a plain film, a CT, or an MRI. At 3 months, there was no improvement in pain or function among patients who had received imaging.5 In other cases, strong professional opinion considers certain tests to be of little value, mainly because alternate tests are preferred or the probability of an abnormal image is exceedingly remote.

There is widespread agreement that more appropriate use of certain imaging tests could both improve quality and save costs. When the American Board of Internal Medicine Foundation asked physician specialty groups to identify procedures or tests that they judged were of little value, imaging tests were frequently identified, such as the use of CT scans for minor head injury in the ED (American College of Emergency Physicians), imaging studies in patients with nonspecific low back pain (American College of Physicians), imaging for uncomplicated headache (American College of Radiology), CT angiography for patients with low clinical probability of pulmonary embolus and a negative D-dimer assay (American College of Chest Physicians), and stress cardiac imaging in patients without high-risk markers for coronary artery disease (American College of Cardiology).

The recognition that more appropriate use of imaging could improve quality and reduce costs has led to the development of interventions to encourage more appropriate radiology utilization. Some of these interventions have made use of the clinical decision support capabilities of electronic health records. VA has been a leader in the use of electronic health records and clinical decision support, and VA leadership therefore requested a review of published studies assessing the effect of electronic health record (EHR)-based interventions to improve the appropriateness of imaging.