# Peer Review Comments/Author Responses

Comment | Author Responses
This is a generally clear and complete report. The authors do a good job of distilling the key findings in a clear way. I have one methods question and a few comments that might make the report more useful for decision makers: 1) on page 9, under outcomes, please describe more completely the different ways that appropriateness and utilization were measured. It appears the most common way was to report appropriateness as a ratio of appropriate/total tests before and after the intervention (as opposed to a rate). However, it isn't clear that the denominator for those ratios was always the same -- only those tests that might have been impacted by the intervention or some that might not have been. I assume utilization was usually reported as a rate of test ordering per patient population, but the ability to detect a change obviously depends a lot on how specifically the population is defined -- all patients in a specific clinic (orthopedic clinic) or all patients with a specific indication for testing (patients with back pain). Given these differences is the assumption of homogenous effect size valid | We have added a new appendix table that indicates exactly the appropriateness outcome used. In all the appropriateness cases, the denominator was the number of radiologic examinations for which the guidelines (or appropriateness criteria, etc) were judged to apply. So we judge it as the same or at least sufficiently similar, constrict in each article to currant pooling (Note: we are not assuming homogenous effect sizes. We are using a random effects analysis, we identified heterogeneity, and attempted to explain some of it.
It would be helpful to translate the effect sizes observed into some more clinically meaningful differences, such as in relative reduction in inappropriate testing, or even # tests averted, based on some reasonable assumptions about the baseline utilization and baseline proportion of inappropriate testing. the terms small or moderate effect otherwise have little meaning to clinicians. Given the larger effects of “hard stop” interventions it would be good to contrast the effects of best interventions (hard stop, audit and feedback, in integrated systems) vs. average, translated into real world estimates. | We have added clinical examples to help readers understand the effect size.
In harms, it would be useful to report whether any studies examined perceived harms of “hard stop” interventions, including burden on clinicians, delays in appropriate testing, inconvenience for patients. | Reporting of hazards was minimal. This is an area needed for future research.
Given report is for VA, it might be good in text and summary included more specific mention of the one VA study. | We added a paragraph about one VA study.
The titles for the figures are potentially confusing -- rather than saying “Implementation Appropriateness” and “Implementation Utilization” I think you mean to say “Effects of Implementation Strategy on Appropriateness…” etc | We have revised the titles for these figures.
This review does a good job of summarizing evidence for EHR-based interventions for reducing unnecessary imaging. I have only minor comments for improvement : 1) Clarify confusion between system (used in key question 2) and settings (used in the rest of the review) | We have clarified that “system” in KQ 2 meant the EHR intervention, not the setting.
2) Explore context issues a bit more in discussion. The findings related to integrated systems perhaps gets to this issue? This is a topic area that this group is very well versed with and it would be good to expand discussion even if it's a limitation that context was not well addressed in detail. | Unfortunately, we've reported as much contextual information as is contained in these articles.
3) Can the review elaborate what was the precise type of advice that the intervention offered; for eg. Do this alternative versus do not do this. I like the 4 types mentioned but some granularity would be good. | We have added more text on this.
4) It would be good to clarify what they mean as audit and feedback upfront. This would be read by a broad audience and it wasn't always clear what was being audited or wo was getting feedback in the authors use of the term | We added specificity about the audit-and-feedback studies.
5) Some discussion of unintended consequences of hard stops is warranted to balance the findings. For eg. Strom et al published about potential harm in Archives. (Unintended Effects of a Computerized Physician Order Entry Nearly Hard-Stop Alert to Prevent a Drug Interaction) | We added the reference to the study by Strom.
6) Can the authors expand on some more specific takeaways for VA operations who want to explore what exactly they should do to respond to the current pressures of reducing costs related to excessive imaging and using technology to do so. For example, could there be other options or other types of CDS that was not found in previous literature? | We judge it beyond our scope for the Evidence Review to make these kinds of recommendations. It would be a great topic for the VA partner to produce.
7) It appears that only the existing database was searched but was anything cross-checked to see if key articles were not left out? For eg. The editorials could have referenced some articles but I am not sure if these were looked at. | We reference-mined all included studies and didn't find any additional eligible studies. We don't think going back and re-doing the decreases in Chaudhry, Goldzweig, Buntin and Jones is likely to be worth the effort.
8) For residents ordering MRI in at least some of the VAs, the template generally displays “Discussed with Attending X”. Has this been studied and what type of intervention will this be? | We did not find such a study in our search. If the ePOE would prohibit an order without this consultation, then we would classify it as a hard stop.
It appears that only the existing database was searched but was anything cross-checked to see if key articles were not left out? For eg. The editorials could have referenced some articles but I am not sure if these were looked at. | We also reference-mind included studies. We don't believe going back and re-doing the searches of Chaudhry, Goldzweig, Buntin and Jones is likely to be worth the effort.