# Description of Outcomes Used as Measures of Appropriate or Inappropriate Use

Study | Method of Reporting Outcome
Day | Was decision appropriate (according to guidelines)?
Chin | % of UGI orders that conformed to a guideline
Carton | % of radiologic examinations not in agreement with guidelines
Rosenthal | Change in rate of radiology orders judged as “low utility” according to appropriateness criteria
Vartanians | % of examinations ordered judged to be of low-yield
Presauer | % of radiology ordering decisions not adherent with the CPSS
Hoo | Yield of positive CT angiography examinations
Raja, 2012 | Yield of positive CT angiography examination
Raja, 2014 | Appropriateness of CT angiography ordering Yield of positive CT angiography examination
Flamm | Numbers of radiology tests indicated or not indicated
Solberg | Proportion of radiology studies meeting “high utility” according to appropriateness criteria
Ip | Guideline adherence rate