# Search Strategies

## Search #1

DATABASE SEARCHED & TIME PERIOD COVERED: PubMed – 1/1/2011-9/10/2014

LANGUAGE: English

SEARCH STRATEGY:

Medical Informatics Applications[MESH:NoExp] OR Decision Making, Computer-Assisted[Mesh:NoExp] OR Decision Support Techniques[Mesh:NoExp] OR Information Systems[Mesh:NoExp] OR Decision Support Systems, Clinical[Mesh] OR hospital Information Systems[Mesh:NoExp] OR Management Information Systems[Mesh:NoExp] OR Medical Order Entry Systems OR automatic data processing[majr] OR medical informatics[majr] OR public health informatics[majr] OR electronics, medical[majr] OR (computers[mh] OR computers, handheld OR microcomputers OR medical records systems, computerized OR computer systems OR software[mh] OR computer-based[tiab] OR computerize*[tiab] OR cpoe OR cdss OR paper chart* OR electronic chart* OR health information technolog* OR electronic medical record* OR emr OR computerized physician order entry OR computerized order entry OR computerize order entry OR electronic health record* OR ehr OR information technology OR e-health OR health information OR hospital information OR health informatic* OR medical informatic* OR Medical Order Entry System* OR information infrastructure* OR ehealth

AND

radiology department OR magnetic resonance imaging OR tomography, x-ray computed OR imaging[tiab] OR radiolog*[tiab] OR neuroradiolog*[tiab] OR tomograph*[tiab] OR x-ray[tiab]

AND

appropriat* OR inappropriat* OR unnecessary OR behavior

AND

test OR tests OR testing

AND

utilization OR utilize OR utilizing OR order* OR request*

NUMBER OF RESULTS: 630

------

## Search #2

DATABASE SEARCHED & TIME PERIOD COVERED: Web of Science – 1/1/2011-9/10/2014

LANGUAGE: English

SEARCH STRATEGY:

FORWARD SEARCHES ON THE FOLLOWING ARTICLES:

Bates DW, Kuperman GJ, Jha A, Teich JM, Orav EJ, Ma'luf N, Onderdonk A, Pugatch R, Wybenga D, Winkelman J, Brennan TA, Komaroff AL, Tanasijevic MJ. Does the computerized display of charges affect inpatient ancillary test utilization?. Arch Intern Med. 1997;157(21):2501-8. [pmid: 9385303].

Sanders DL, Miller RA. The effects on clinician ordering patterns of a computerized decision support system for neuroradiology imaging studies. Proc AMIA Symp. 2001:583-7. [pmid: 11825254].

Carton M, Auvert B, Guerini H, Boulard J-C, Heautot J-F, Landre M-F, Beauchet A, Sznajderi M, Brun-Ney D, Chagnon S. Assessment of radiological referral practice and effect of computer-based guidelines on radiological requests in two emergency departments. Clinical radiology. 2002;57(2):123-128. [pmid: 11977945].

Vartanians VM, Sistrom CL, Weilburg JB, Rosenthal DI, Thrall JH. Increasing the Appropriateness of Outpatient Imaging: Effects of a Barrier to Ordering Low-Yield Examinations 1. Radiology. 2010;255(3):842-849. [pmid: 20501721].

NUMBER OF RESULTS AFTER REMOVING DUPLICATES: 114

-----

## Search #3

DATABASE SEARCHED & TIME PERIOD COVERED: PubMed – 1/1/2011 - 9/10/2014

LANGUAGE: English

SEARCH STRATEGY:

RELATED ARTICLE SEARCHES ON THE FOLLOWING ARTICLES:

Bates DW, Kuperman GJ, Jha A, Teich JM, Orav EJ, Ma'luf N, Onderdonk A, Pugatch R, Wybenga D, Winkelman J, Brennan TA, Komaroff AL, Tanasijevic MJ. Does the computerized display of charges affect inpatient ancillary test utilization?. Arch Intern Med. 1997;157(21):2501-8. [pmid: 9385303].

Sanders DL, Miller RA. The effects on clinician ordering patterns of a computerized decision support system for neuroradiology imaging studies. Proc AMIA Symp. 2001:583-7. [pmid: 11825254].

Carton M, Auvert B, Guerini H, Boulard J-C, Heautot J-F, Landre M-F, Beauchet A, Sznajderi M, Brun-Ney D, Chagnon S. Assessment of radiological referral practice and effect of computer-based guidelines on radiological requests in two emergency departments. Clinical radiology. 2002;57(2):123-128. [pmid: 11977945].

Vartanians VM, Sistrom CL, Weilburg JB, Rosenthal DI, Thrall JH. Increasing the Appropriateness of Outpatient Imaging: Effects of a Barrier to Ordering Low-Yield Examinations 1. Radiology. 2010;255(3):842-849. [pmid: 20501721].

RESULTS AFTER REMOVING DUPLICATES: 49