# References

1 Bernstein SL, Aronsky D, Duseja R, The effect of emergency department crowding on clinically oriented outcomes. Acad Emerg Med. 2009;16(1):1–10.19007346
2 Asplin BR, Magid DJ, Rhodes KV, Solberg LI, Lurie N, Camargo CA, Jr. A conceptual model of emergency department crowding. Ann Emerg Med. 2003;42(2):173–180.12883504
3 Doupe M, Chateau, D., Derksen, S., Sarkar, J., de Faria, R. L., Strome, T., Soodeen, R., McCulloch, S., Dahl, M. Factors Affecting Emergency Department Waiting Room Times in Winnipeg. Manitoba Centre for Health Policy; 2017.
4 Abdulwahid MA, Booth A, Kuczawski M, Mason SM. The impact of senior doctor assessment at triage on emergency department performance measures: systematic review and meta-analysis of comparative studies. Emerg Med J. 2016;33(7):504–513.26183598
5 Saghafian S, Austin, G., & Traub, S. J. Operations research/management contributions to emergency department patient flow optimization: Review and research prospects. IIE Transactions on Healthcare Systems Engineering. 2015;5(2):101–123.
6 Elder E, Johnston AN, Crilly J. Review article: systematic review of three key strategies designed to improve patient flow through the emergency department. Emerg Med Australas. 2015;27(5):394–404.26206428
7 Miake-Lye IM, Hempel S, Shanman R, Shekelle PG. What is an evidence map? A systematic review of published evidence maps and their definitions, methods, and products. Syst Rev. 2016;5:28.26864942
8 Ogrinc G, Davies L, Goodman D, Batalden P, Davidoff F, Stevens D. SQUIRE 2.0 (Standards for QUality Improvement Reporting Excellence): revised publication guidelines from a detailed consensus process. BMJ Qual Saf. 2016;25(12):986–992.
9 Soremekun OA, Biddinger PD, White BA, Operational and financial impact of physician screening in the ED. Am J Emerg Med. 2012;30(4):532–539.21419587
10 Han JH, France DJ, Levin SR, Jones ID, Storrow AB, Aronsky D. The effect of physician triage on emergency department length of stay. J Emerg Med. 2010;39(2):227–233.19168306
11 Fernandes CM, Christenson JM, Price A. Continuous quality improvement reduces length of stay for fast-track patients in an emergency department. Acad Emerg Med. 1996;3(3):258–263.8673783
12 Partovi SN, Nelson BK, Bryan ED, Walsh MJ. Faculty triage shortens emergency department length of stay. Acad Emerg Med. 2001;8(10):990–995.11581086
13 Ardagh MW, Wells JE, Cooper K, Lyons R, Patterson R, O’Donovan P. Effect of a rapid assessment clinic on the waiting time to be seen by a doctor and the time spent in the department, for patients presenting to an urban emergency department: a controlled prospective trial. N Z Med J. 2002;115(1157):U28.12362191
14 Richardson JR, Braitberg G, Yeoh MJ. Multidisciplinary assessment at triage: a new way forward. Emerg Med Australas. 2004;16(1):41–46.15239754
15 Terris J, Leman P, O’Connor N, Wood R. Making an IMPACT on emergency department flow: improving patient processing assisted by consultant at triage. Emerg Med J. 2004;21(5):537–541.15333523
16 Rodi SW, Grau MV, Orsini CM. Evaluation of a fast track unit: alignment of resources and demand results in improved satisfaction and decreased length of stay for emergency department patients. Qual Manag Health Care. 2006;15(3):163–170.16849988
17 Levsky ME, Young SE, Masullo LN, Miller MA, Herold TJ. The effects of an accelerated triage and treatment protocol on left without being seen rates and wait times of urgent patients at a military emergency department. Mil Med. 2008;173(10):999–1003.19160619
18 Ieraci S, Digiusto E, Sonntag P, Dann L, Fox D. Streaming by case complexity: evaluation of a model for emergency department Fast Track. Emerg Med Australas. 2008;20(3):241–249.18462407
19 Singer AJ, Viccellio P, Thode HC, Jr., Bock JL, Henry MC. Introduction of a stat laboratory reduces emergency department length of stay. Acad Emerg Med. 2008;15(4):324–328.18370985
20 Gerton JS, E.; Pimentel, L.; Ercolano, P.; Browne, B.; Barrueto, F. When is a physician in triage a financially viable option? Acad Emerg Med. 2009;16(4):S272.
21 Arya R, Salovich DM, Ohman-Strickland P, Merlin MA. Impact of scribes on performance indicators in the emergency department. Acad Emerg Med. 2010;17(5):490–494.20536801
22 Fry MF, J.; Asha, S.; Arendts, G. A 12-month evaluation of the impact of Transitional Emergency Nurse Practitioners in one metropolitan Emergency Department. Australasian Emergency Nursing Journal. 2011;14(1):4–8.
23 Imperato J, Morris DS, Binder D, Physician in triage improves emergency department patient throughput. Intern Emerg Med. 2012;7(5):457–462.22865230
24 Soremekun OA, Capp R, Biddinger PD, Impact of physician screening in the emergency department on patient flow. J Emerg Med. 2012;43(3):509–515.22445677
25 Soremekun OA, Shofer FS, Grasso D, Mills AM, Moore J, Datner EM. The effect of an emergency department dedicated midtrack area on patient flow. Acad Emerg Med. 2014;21(4):434–439.24730406
26 Inokuchi R, Sato H, Iwagami M, Impact of a New Medical Record System for Emergency Departments Designed to Accelerate Clinical Documentation: A Crossover Study. Medicine. 2015;94(26):e856.26131837
27 Day TE, Al-Roubaie AR, Goldlust EJ. Decreased length of stay after addition of healthcare provider in emergency department triage: a comparison between computer-simulated and real-world interventions. Emerg Med J. 2013;30(2):134–138.22398851
28 Saghafian S, Hopp WJ, Van Oyen MP, Desmond JS, Kronick SL. Patient streaming as a mechanism for improving responsiveness in emergency departments. Operations Research. 2012;60(5):1080–1097.
29 Laker LF, Froehle CM, Lindsell CJ, Ward MJ. The flex track: flexible partitioning between low-and high-acuity areas of an emergency department. Annals of emergency medicine. 2014;64(6):591–603.24954578