# Summary and Discussion

This review illustrates several gaps in the evidence base for interventions improving ED efficiency. First, very few studies reported utilization, cost, and quality of care outcomes together. Two-thirds of studies reported data for LOS, and less than half reported data for WT or LWBS. Only a small fraction reported on patient harms or medical errors. When authors do not provide a full accounting of an intervention’s effects, this limits the ability of other leaders to apply the findings of an improvement study.^3^

Second, only a minority of studies quantified the resources required to implement an intervention. One-third were unclear even as to whether additional resources would be needed. Costly interventions are not necessarily more effective in improving efficiency. For example, simply increasing ED capacity is thought to be a straightforward fix for overcrowding, but this is expensive, rarely practical in the short-term, and not always beneficial.^28^ As ED leaders and decision-makers are often faced with resource constraints, more accurate reporting of resource requirements is imperative.

Lastly, we found 7 studies that demonstrated improvements in efficiency outcomes solely through reallocating existing resources. These studies represented 4 different intervention types (physician triage, fast track, nurse scope of practice expansion, and care teams). Researchers should prioritize understanding how these interventions effected improvements at relatively little cost. Generalizing these lessons could be transformative in improving ED throughput. That said, most studies using these 4 intervention types actually added resources, emphasizing the need to describe organizational context in better detail. If more resources were needed, why? And if existing resources could be reallocated, what factors within the organization helped facilitate this? The SQUIRE guidelines for quality improvement interventions provide a model for reporting contextual information.^8^

## Limitations

Several factors may limit interpretation of this report. We excluded simulation studies from the evidence map, as we focused on interventions tested in the real world, which are likely more useful to decision-makers. Additionally, the results of simulation studies are not directly comparable to results from implementations in practice, as a recent review of operations research/operations management (OR/OM) in regard to ED overcrowding suggests that a disconnect between theory and practice remains,^5^ and it would be inappropriate to display them together in the evidence map. Regardless, simulation and OR/OM approaches have been beneficial for predicting the effects of policy changes, especially in resource-poor environments like EDs that may not have the resources to formally test many interventions or policies. For example, a recent simulation study based on one urban level 1 trauma center with 85,000 annual visits examined the effect of “flexing” a certain number of Fast Track beds (where Fast Track can be used to accommodate higher-acuity patients according to operational demands) on ED LOS.^29^ For their 50-bed ED with a 10-bed Fast Track, they found that allowing up to 3 Fast Track beds to be “flexed” resulted in an optimal improvement in ED LOS. There is a role for simulation approaches, provided that the findings can be subsequently tested in actual practice settings.

The outcome measures included in this synthesis raise challenges as well. Outcomes like LOS can be measured in different ways (e.g., bed assignment to final disposition, arrival-to-exit, etc), introducing issues with cross-study comparisons. The included publications varied both in the extent to which they provided definitions for the outcome measures they used, and in how they measured outcomes when this was reported. Outcomes that are relatively rare, such as LWBS, or outcomes that may have distributional challenges such as outliers, require additional consideration. Inspecting both the definitions of outcome measures and the measures of variability would be important data to gather in a formal systematic review, but would require detailed reading of each included study that goes beyond the scope of the data abstraction for an evidence map. This type of analysis would typically focus on a more narrow scope, such as a particular intervention or particular outcome.

While data limitations and the broad scope of inquiry for this mapping synthesis prevent us from performing statistical tests of publication bias, such bias is almost certainly present, as ED efficiency is an issue fundamental to the operations of any ED, and it is unlikely that all experiences have been written up for publication. Less successful implementations of interventions to improve ED efficiency may be the most vulnerable to being excluded from formal publication and consequently from our synthesis, but even successful implementations may not be published, so we cannot speculate as to how these interventions might impact the findings we present. Also, while the evidence map approach can generate insights into the state of the literature, they are not an exhaustive systematic review or meta-analysis, and do not provide the degree of comprehensiveness or statistical precision expected of those types of reviews. Despite these limitations, this review has highlighted several important gaps in the literature and identified priorities for future research efforts.

## Future Work

To better understand the value of ED efficiency interventions, increased measurement and reporting of costs or value-related data is necessary. The large variability in wait times and length of stay data also suggest that these may be measured different ways in different studies, and standardization in future work, or more detailed description about these calculations, would also be helpful. Most data came from single sites, which may have unique circumstances, so larger studies of multiple sites would also increase knowledge in this area. In addition, to better connect theory and practice, a greater understanding of why particular interventions are expected to improve efficiency is needed. Finally, because VA is a unique context with only one publication describing an ED efficiency intervention, more work within VA would be helpful in understanding which of the various interventions might work best in VA’s particular circumstances. As health care needs continue to increase, EDs are likely to face ever-growing patient loads, so finding and describing the best practices for optimizing ED efficiency remains imperative.