# Results

## Literature Flow

Our literature searches identified 139 titles as potentially relevant for this evidence map. From these titles, 133 references were included for full-text review. Six were excluded from full-text review because 5 were pre-1996 and one was unavailable. When reviewing full texts, 36 publications were rejected for the following reasons: 3 were pre-1996; 15 did not have an outcome of interest (ie, study focused on improvements for a single condition only or no ED outcome was measured); 12 did not include an ED efficiency intervention; 3 did not have an intervention; 2 were not an ED study; 3 were systematic reviews; 2 were not retrievable; and one was a duplicate of another publication included for review. A full list of studies excluded at full-text review is included in Appendix E.

The 97 included publications described 11 categories of interventions: 32 described triage by a physician, 23 described expanding nurse scope of practice (SOP), 12 described fast track interventions, 6 described point of care (POC) testing, 4 described information technology-based (IT) interventions, 4 described rapid assessment units, 3 described the use of medical scribes, 2 described observation units, 2 described team triage, and 7 described other interventions that only appeared once. Examples of intervention types reported in one study each included sharing individual performance data to all providers, intensive bed occupancy tracking, geriatric focused areas, and comprehensive department re-engineering. A full list of included studies is included in Appendix D. See Figure 1 for the Literature Flow.

Figure 1 Literature Flow Chart

RCT = randomized controlled trial

NRT = non-randomized concurrently controlled trial

Time = time-series

P/P = pre/post

Table 1 presents descriptive information about the 97 included studies. Studies originated from the United States (41%), Australia (19%), Canada (11%), the United Kingdom (9%), and 13 other nations (19%). Studies were usually located at academically affiliated sites (73%), and 93% were single-site interventions. Samples sizes ranged, with 60% of studies including more than 1,000 patients, 37% of studies including more than 10,000 patients, and 14% of studies using shifts or facilities as the unit of analysis. Only one study was at a VA site. The most common study design was pre/post design (43%).

Table 1 Descriptive Information about the Studies

Country of Origin | Sample size = 97
USA | 40
Australia | 19
Canada | 11
UK | 9
Other | 18
Site Academically Affiliated
Yes | 69
No | 11
Both | 2
Not reported | 15
Sites Involved
One site | 90
Multi-site | 6
Not reported | 1
Sample Sizes
>10,000 patients | 36
1,000-9,999 patients | 22
500-999 patients | 7
100-499 patients | 16
Other unit (shift, facility) | 14
Unclear | 2
VA Setting
No | 96
Yes | 1
Study Design
Randomized controlled trial | 7
Non-randomized concurrently controlled trial | 31
Time series | 14
Pre/post | 42
Other | 3

## Utilization, Quality, and Safety Reported

Reporting of ED utilization outcomes varied, with LOS reported by 69% (n=67), WT by 38% (n=37), and LWBS by 35% (n=34). Other outcomes reported included the inpatient admission rate (33% of studies, n=32), other clinical outcomes such as unplanned revisit rate (13%; n=13), and clinical harms (8%; n=8). In terms of data showing impact on clinical quality, 13% reported clinical measures (eg, health status or patient satisfaction). 13% reported unplanned revisit rates, and 8% reported clinical harms.

## Costs and Resource Use Reported

Reporting of costs was limited, as 20% of studies provided a quantitative estimate of implementation requirements (n=19). We were necessarily generous when determining that studies met the criterion for quantifying costs. Table 3 presents abridged examples of actual text from articles, while Appendix F presents the unabridged examples. These varied from formal cost-effectiveness analyses, such as in the study by Soremekun,^9^ to stating a physician was added and what amount of time was necessary (such as in the study by Han^10^). In reporting implementation resource requirements: 44 studies described adding new resources (45%), 18 studies described reallocating existing resources (19%), and 35 studies were unclear in regard to net resource expenditure (36%, lacked sufficient description).

Table 2 Abridged Examples of Key Text Counted as “Quantifying Costs”

Fernandez, 1996^11^ | Prior to the present study, no nurse was assigned solely to the FT area. “… addition of an extra admitting clerk; … addition of an FT nurse; … we expanded our FT area to include more rooms and stretchers, … having a full-time FT nurse”
Partovi, 2001^12^ | “The cost of additional faculty coverage was estimated to be $11.98/patient seen in ED. … If this is to be implemented on a fulltime basis, the cost per patient would rise to $19.35. The annual cost will be more than a million dollars for full-time faculty triage.”
Ardagh, 2002^13^ | “an additional nurse and an additional ED registrar were rostered”
Richardson, 2004^14^ | “… it was necessary to increase the evening consultant cover from one to two consultants… Staff were educated… the department was modified to include a desktop working area for the MDT doctor and a mini assessment/treatment cubicle behind the triage desk… A diagnostic set and X-ray viewing box was installed on the wall.”
Terris, 2004^15^ | “Funding was allocated for senior clinicians (medical and nursing) to staff the triage area for 16 hours per week for three months. An emergency medicine consultant and a senior ED nurse (G or F grade) were chosen as the preferred team.”
Rodi, 2006^16^ | “The only new cost of the intervention was hiring a dedicated technician to support the PA.”
Levsky, 2008^17^ | “…an emergency physician or physician’s assistant, a registered nurse, and a medic or civilian emergency medical technician… During the intervention, the TNT team was used 4 days a week: Monday, Tuesday, Thursday, and Sunday from 10:00 a.m. to 6:00 p.m. … Specifically, during PI, five new registered nurses were hired, as were three new medical support assistants (clerks), which increased nurse and clerk coverage by approximately 7% and 15%, respectively. No ED operations or staffing changes occurred between P2 and P3, other than the addition of TNT.”
leraci, 2008^18^ | “The net result of the remodelling was a reduction in the total number of treatment spaces (beds plus chairs) from 25 to 24… Separate clinical resources were provided to staff the FT area with two nurses round the clock, and one senior doctor (career medical officer, CMO) for 16 h/day.”
Singer, 2008^19^ | “The third phase involved hiring seven personnel, at a laboratory technologist level, so that a new workstation could be covered 24 hours per day in the central laboratory, 7 days per week. It also involved the purchase of new analyzers, at a cost of about $46,000, and installation of a dedicated pneumatic tube, at a cost of about $150,000.”
Gerton, 2009^20^ | “The PIT provided additional coverage that replaced a triage nurse, but did not change the physician staffing of the ED… During PIT hrs, 11.5 RVUs more were billed on average than without PIT (384 vs. 373; 95% CI +/-41). With RVU estimated at $38.08, charges increased by $438 / 8hr shift. If PIT were 5 d/wk for 1 yr, increased billing would be $118,000. This would not offset the cost of a physician.”
Arya, 2010^21^ | “The scribe training program is 60 hours in length.” “The RVU/hr increased by 0.18 (95% confidence interval [CI] = 0.04 to 0.32, p = 0.0067) units when the percentage of a shift for which a scribe was utilized increases by 10%… If a physician in our department changed from 0% to 100% of the patients seen with a scribe, 0.8 additional patients per hour can be evaluated in a 10-hour shift, and 24 (2.4/hr) additional RVUs would be generated… Based on the 2008 Medicare RVU reimbursement rate of $38 for one RVU, a scribe being utilized to full capacity, resulting in an additional 2.4 RVUs/hr generated, could result in an additional 91 billed dollars per hour. Scribes at our institution are salaried at approximately $16–$19 per hour…”
Han, 2010^10^ | Physician triage was initiated on July 11, 2005, 7 days a week from 1:00 p.m. to 9:00 p.m. A dedicated board certified or board-eligible emergency physician initiated diagnostic evaluation and treatment of patients in the waiting room after the triage nurse performed his or her initial evaluation. The triage physician was an additional physician to the existing staffing model.
Fry, 2011^22^ | “The TENP role, in July 2006, commenced with the employment of 3 full time equivalent positions, which provided a TENP on duty for 15 h a day Monday– Sunday (eight o’clock am to eleven o’clock pm).” (TENP = Transitional Emergency Nurse Practitioner)
Imperato, 2012^23^ | “…required the addition of two full-time equivalent attending physicians, at a total cost of $490,000 in additional salary costs per year plus fringe benefits. The nurse and technician assigned to the PIT were reallocated from another part of the ED, so no additional nursing staffing cost was incurred.”
Soremekun, 2012^9^,^24^ | “Three components of the financial impact of the physician triage were considered: revenue, operational costs, and capital expenditure… The incremental revenue and operational expense projection generated from physician screening using aforementioned assumptions are depicted in Table 4. In year 1, the estimated ED contribution margin from discharged patients is $1 324 338 (growth in medium acuity patients, $1 137 234; LWBS patients, $187 104) and the estimated contribution margin from admitted patients is $1 384 718. The estimated operational expense associated with the physician screening system at year 1 is $1 864 104 ($1 624 104 in salary costs; $240 000 in depreciation costs). The total earnings and CF projection at year 1 are $844 952 and $1 084 952, respectively. Based on the CF projections and a discount rate of 5%, the NPV of physician screening was $2 816 263 and the internal rate of return is 85%, with time to break even of 13 months.”
Soremekun, 2014^25^ | “The midtrack area, however, was staffed with two additional registered nurses (RNs) for an additional 16 hours or a 3.4% increase in total nursing clinical hours per day.”
Inokuchi, 2015^26^ | “… the system can be built for less than 5000 US dollars”

Utilization data, resource requirements, quantifiable input costs, and quality outcome measures were reported together by 3 of 97 studies (3%). All three were single-site studies, and all three required the addition of new resources. A pre/post study of emergency nurse practitioners from an Australian academic medical center^22^ required the addition of 3 FTE nurse practitioners, and yielded a 3% improvement in LOS (207 vs 213 minutes, p < .0001), a 36% improvement in WT (38 vs 60 minutes, p < .000), and a 44% reduction in LWBS (8.1% vs 4.5%, p < .0001). Of 5,248 patients seen by nurse practitioners, there was one case of missed early appendicitis, and one case of missed nondisplaced hand fracture, but no adverse outcomes. A fast track intervention, using a pre/post study design at an Australian academic medical center^18^ required an increase in total staff time of 16%, and yielded an 19% improvement in LOS (194 vs 241 minutes, p < .001), a 42% improvement in WT (32 vs 55 minutes, p < .001), and a 50% improvement in LWBS (3.1% vs 6.2%, p < .001). However, re-presentation to the ED within 48 hours increased slightly (4.4% vs 3.7%, p = .056). A new EMR deployment at a Japanese academic medical center^26^ yielded a 19% reduction in length of stay (108 mins vs 134 mins, p < .001), with no significant change in 28-day mortality (0.4% vs 0.7%, p = .62). This study used a crossover design to provide a concurrent comparison group.

## Description of Resource Use by Intervention Type

Physician triage was the most commonly studied intervention, and nearly half of the studies where costs were quantified were from physician triage studies (47%, see Figure 2). Expanding nurses’ scope of practice was the next most common intervention, but only one study quantified costs.

Figure 2 Intervention Type with Costs Quantified

Our first evidence map presents the studies by intervention type and description of resource use (Figure 3). Four intervention types (physician triage, expanding nurses’ scope of practice, fast track, and care teams) were implemented at least once without requiring the addition of new resources to the ED. However, for each of these types, it was more commonly reported that additional resources were required. There were 6 intervention types that were never implemented through reallocating existing resources only: point of care testing, rapid assessment units, information technology (IT) interventions, medical scribes, team triage, and observation units.

Figure 3 Evidence Map Displaying Amount of Literature by Intervention and Resource Use Reported (n=97)

## Effect on Length of Stay by Intervention Type

Most studies that reported changes in length of stay (n=67) improved mean LOS by between 10 and 40 minutes. When these improvements are displayed as a percentage relative to baseline LOS, improvements tended to range between 5% and 20% (Figure 4). Fast Track and Nurse Scope of Practice interventions had the highest frequency of studies that were able to yield improvements greater than 30%. No Medical Scribe studies reported Length of Stay outcomes.

Figure 4 Evidence Map Displaying Improvement in Length of Stay (Percent Change from Baseline)

## Effect on Wait Time by Intervention Type

Improvements in wait time tended to range between 10 and 40 minutes, or 10% to 50% of baseline (Figure 5). Physician Triage and Nurse SOP had the highest number of studies with very high improvements of more than 60%. No IT, Medical Scribe, Observation Unit, or Point of Care Testing interventions reported effects on Wait Time.

Figure 5 Evidence Map Displaying Improvement in Wait Time (Percent Change from Baseline)

## Effect on LWBS by Intervention Type

Most interventions yielded reductions in LWBS ranging between 0 and 5 absolute percentage points from their baseline rate. Compared to baseline LWBS, improvements ranged from −0.5% to 64.7% (Figure 6). Physician Triage and Nurse Scope of Practice had the most number of consistently positive results. Fast Track yielded both strongly positive and negative results. No Medical Scribe, Observation Unit, or Point of Care Testing interventions reported effects on LWBS rate.

Figure 6 Evidence Map Displaying Change in Left Without Being Seen Rate (Percent Change from Baseline)

## VA Publications

Of the 97 included publications, there was one study conducted in the VA from the St. Louis VA Medical Center.^27^ This single-site study included 2,194 patient visits pre-intervention and 2,154 patient visits post-intervention and describes the reassignment of a physician and nurse practitioner to triage, as well as the results of a discrete event simulation modelling the same conditions. The modelling accurately predicted the effect of the intervention, which decreased the daily mean LOS from 247 to 210 minutes (p < .001) and the number of patients with LOS above 6 hours from 19.9 percent to 14.3% (p < .0001).