# Methods

## Topic Development

This topic was developed in response to a nomination by Dr. Michael Ward on behalf of Dr. Chad Kessler, National Director of the VA Emergency Medicine Field Advisory Committee. This report contributed to the Field Advisory Committee’s conference “Toward a VA Emergency Medicine Research Agenda: Setting Priorities to Improve the Health of Veterans Seeking Emergency Care.” The scope was further developed with input from the topic nominators, the ESP Coordinating Center, the review team, and the technical expert panel (TEP).

The scope of this report includes the following:

- An evidence map that provides a visual overview of the distribution of evidence (both what is known and where there is little or no evidence base) for interventions to improve emergency department (ED) efficiency.
- An accompanying narrative that helps stakeholders interpret the state of the evidence to inform policy and clinical decision-making.

## Search Strategy

A literature search conducted by the VA Evidence-Based Synthesis Program (ESP) Coordinating Center identified peer-reviewed journal articles reporting ED efficiency improvement interventions, including systematic reviews, which were mined for references. Multiple databases were included: Cochrane Database of Systematic Reviews: Protocols and Reviews (2005 through July 20, 2016), MEDLINE (1996 through July 21, 2016), as well as sources of gray literature (see Appendix A for full search strategy).

## Inclusion/Exclusion Criteria

To be considered as evidence for inclusion in the evidence map, each study must have tested the effectiveness of an intervention on one or more specific measures of ED utilization, including, but not limited to, length of stay (LOS), waiting room time (WT), or left without being seen (LWBS) rate. These include both randomized controlled trials and observational studies, and comparisons across institutions or within an institution over time. Studies not providing data on outcome measures, focusing only on a single clinical condition (eg, acute myocardial infarction), and simply using inpatient units to offload ED functions (eg, condition-specific, short-term observation units) were excluded. Studies published more than 20 years ago were excluded.

## Study Selection and Data Abstraction

All citations were reviewed by 2 independent reviewers (PGS/SMO or MMG/CPC). Data extraction and full-text review were completed in duplicate as well. Discrepancies were resolved with discussion among the reviewer pairs. Full study selection criteria and data abstraction fields are listed in Appendix B.

We abstracted: unit of analysis, sample size, country, hospital teaching status, type(s) of utilization, cost and quality impact measures reported, and baseline and post-intervention results. Relative improvement in outcomes was calculated as a positive percentage improvement over baseline (eg, a reduction in LOS from 90 minutes to 60 minutes would be a ([90–60]/90 = 33% improvement). If studies presented multiple versions of a particular outcome, we defined LOS as the total time from ED bed assignment to final disposition (eg, discharge or transfer to an inpatient unit), WT as the total time from arrival in the waiting room to ED bed assignment, and LWBS rate as the percentage of all analyzed visits in which a patient leaves from the ED before being seen by a physician. While there was heterogeneity in the use of these terms by study authors, we used the data provided by the authors if they reported using the same term.

We identified the measures of implementation cost that were reported and quantified (eg, full-time-equivalents [FTEs] added, equipment costs). If costs weren’t quantified, we ascertained whether implementation was described as being accomplished by reallocating existing resources, or whether it was described as requiring new resources. Studies that described both reallocation of existing resources and new resources were classified as requiring new resources.

Studies were classified by intervention, each study was assigned to one intervention type to produce exhaustive and mutually exclusive categories. In cases where studies could overlap categories, best fit was determined with group review. We used categories from previous systematic reviews when possible and pile sort techniques otherwise.

## Quality Assessment

This is not applicable for an evidence map.

## Data Synthesis

An evidence map is a systematic search of a broad field to identify gaps in knowledge and future research needs, which presents the results in a user-friendly format, often a visual figure or graph, or a searchable database.^8^ In our case, an overview map plotted the distribution of intervention types (x-axis) with resources required for implementation (y-axis). Studies were grouped according to these dimensions and plotted as bubbles, the size of which represented the number of studies in that group. The color of the bubble additionally corresponds to the nature of resource use of a study.

A second set of evidence maps illustrated intervention types (x-axis, major sections), resources required for implementation (color and x-axis, minor sections), effect size (y-axis), and study size (diameter of markers). These maps are not intended to pool data, but to illustrate the evidentiary landscape in regard to interventions to improve ED efficiency. Findings from these maps were derived through observation and discussion among co-authors.

## Narrative Synthesis

The narrative synthesis complements the visual evidence maps to provide more details from the included literature.

## Technical Expert Panel

The technical expert panel (TEP) for the project included: Chad S. Kessler, MD, National Program Director, VA Emergency; Michael Ward, MD, Department of Emergency Medicine, Vanderbilt University Medical Center, VA; Kristina Cordasco, MD, Core Investigator, VA Greater Los Angeles Center for the Study of Healthcare Innovation, Policy and Practice.

## Peer Review

A draft version of the report was reviewed by technical experts and clinical leadership. Reviewer comments and our responses are documented in Appendix C.