# Evidence Report

## Introduction

### Background

Overcrowding in the emergency department (ED) negatively affects patient outcomes, limits effective treatment for time-sensitive conditions such as pneumonia and sepsis, and reduces the safety and timeliness of care.^1^–^3^ “Efficiency” in ED care is often assessed by using measures of utilization (eg, length of stay [LOS] or waiting time), but in order to be relevant to policymakers needs also to include a measure of the unit of resources expended (eg, physician full-time-equivalents) to implement the intervention, and some assessment of quality (eg, the same or fewer harms and errors). Many ED efficiency interventions have been described, ranging from structural redesign (eg, “fast track” units) or staffing changes (eg, medical scribes) to technological solutions (eg, point-of-care lab testing).

### Importance

Given the large number and breadth of interventions described, a systematic scoping review describing the full range of the evidence would be helpful to clinicians, administrators, and researchers. Previous reviews limited their focus to one or several intervention types, such as physician triage^4^ or expanding nurses’ scope of practice.^5^ Some reviews included multiple types^6^ but none have sought to purposefully include a broad range of interventions. Simulation of ED throughput is a robust field of inquiry, but few of these models are implemented and tested in real-world settings.^5^,^7^

### Goals of this Investigation

In order to make decisions on strategic priorities, ED leaders need efficiency intervention studies to be clear and specific, to reflect tests in real-world settings, to define the organizational context of the intervention, and to report utilization outcomes, costs, and impacts on quality of care such as harms or errors. We sought to broadly describe a range of ED efficiency improvement studies using evidence mapping. This approach identifies gaps in knowledge by presenting results in a graphical format to highlight future research needs.^8^