# APPENDIX F Unabridged Examples of Text Counted as “Quantifying Costs”

Fernandez, 1996^11^ | “The ED is staffed 24 hours per day by full-time, certified emergency physicians (EPs). Senior medical students, interns, and residents also are in attendance. There are eight to nine staff nurses per 12-hour shift, including one triage nurse. All patients are seen by the triage nurse and classified according to acuity of complaint. Patients then see an admitting clerk to provide demographic information. Patients are sent to one of two areas: FT or acute care. Prior to the present study, no nurse was assigned solely to the FT area.” “ Nine solutions were identified: 1) addition of an extra admitting clerk; 2) a streamlined FT process; 3) expansion of the FT area; 4) a new triage classification; 5) addition of an FT nurse; 6) a defined triage nurse role; 7) addition of a unit coordinator; 8) an ED switchboard; and 9) addition of floor color codes/ signs with a more accessible information desk. In Phase I, we added the extra admitting clerk and streamlined the FT process. In Phase II, we expanded our FT area to include more rooms and stretchers, implemented a stricter, more detailed triage classification (Table I), and dedicated a nurse to the FT area whose previous responsibilities had been poorly defined.” “During the post-Phase II period, the staffing of the FT area, other than having a full-time FT nurse, was identical to that of the control period and the two other post-Phase I study periods.”
Partovi, 2001^12^ | “We compared the effect of adding a faculty member to ED triage on patients’ LOS versus patients’ LOS when existing nursing triage practices were used….On eight of the Mondays, triage was conducted as usual with the ED staff of two nursing personnel and one EMT. On the remaining eight Mondays an ED faculty member was added to the regular staff of the triage area for the period under study.” “The cost of additional faculty coverage was estimated to be $11.98/patient seen in ED. This was simply calculated by dividing triage faculty cost [(number of hours in triage)(hourly wage)] into total number of patients seen in the ED during the study hours. If this is to be implemented on a fulltime basis, the cost per patient would rise to $19.35. The annual cost will be more than a million dollars for full-time faculty triage. We did not study changes in physician charges resulting from FT. We conclude that FT offers an increase in efficiency but with relatively high cost.”
Ardagh, 2002^13^ | “Forten weeks… an additional nurse and an additional ED registrar were rostered a 0900 to 1700hr shift Monday to Friday. On the odd weeks, these two staff ran a RAC and on even weeks, they did not run a RAC, but simply joined the other medical and nursing staff, managing patients in the traditional way”
Richardson, 2004^14^ | “It was decided that MDT would run only when there were two consultants in the ED, one at triage and one to continue in the traditional consulting role on the floor. It was also decided to target evening shifts as these were the busiest and associated with the most bed and cubicle access block. Hence, it was necessary to increase the evening consultant cover from one to two consultants. This was achieved by roster changes, and restricting the coverage to Monday to Friday… Staff were educated prior to the introduction of MDT… There was also extensive education for junior medical staff to ensure that the triage assessment did not prevent the appropriate provisional diagnosis being made ‘downstream’. The physical design of the department was modified to include a desktop working area for the MDT doctor and a mini assessment/treatment cubicle behind the triage desk. Patients were assessed in a reclining chair with a curtain screen for privacy. An IV insertion, venepuncture, dressing pack and bandages trolley were supplied. A diagnostic set and X-ray viewing box was installed on the wall.”
Terris, 2004^15^ | “Medical staffing includes five consultant emergency physicians, 10 specialist registrars, and 25 junior SHOs. Primary care providers are rostered up to 50 hours cover per week. There are 124 WTE nursing staff, including eight emergency nurse practitioners. Funding was allocated for senior clinicians (medical and nursing) to staff the triage area for 16 hours per week for three months. An emergency medicine consultant and a senior ED nurse (G or F grade) were chosen as the preferred team.”… “In our study the effect of the additional resources was not directly measured, we acknowledge that increasing the overall staffing complement by a consultant plus a senior nurse would be expected to give some improvement in the parameters measured whether IMPACT was occurring or not. Although our staffing levels are generally high in comparison with national standards, current resources within our department are inadequate for IMPACT to operate on a full time basis, but where staffing levels permit, we feel it to be a useful tool for managing flow at times of peak attendance. Clearly in departments without our overall level of staffing it would be difficult to provide an IMPACT type service, let alone sustain it for any period of time. Even with the extra staff only 23 of the intended number of 48 IMPACT sessions could be completed because of staffing shortages on some days, and although our intention was that the IMPACT team should have no other duties during that time, this did not always happen. The direct and indirect costs of such a service would be considerable and this pilot project was not designed to provide a formal cost effectiveness analysis. It may well be that while IMPACT can provide us with the tangible benefits shown in this study the money required to even partially fund such a service could produce even greater benefits elsewhere within the ED, we have not measured such opportunity costs in this paper.”
Rodi, 2006^16^ | “The PAs were already on staff and had been previously seeing patients (identified as low acuity by the Canadian Emergency Department Triage and Acuity Scale [CTAS]) in the main ED. The only new cost of the intervention was hiring a dedicated technician to support the PA.”
Levsky, 2008^17^ | “If a patient meets EC3 criteria and no beds are available in the main ED, they are seen as soon as possible by a “TNT team,” consisting of an emergency physician or physician’s assistant, a registered nurse, and a medic or civilian emergency medical technician.” “During the intervention, the TNT team was used 4 days a week: Monday, Tuesday, Thursday, and Sunday from 10:00 a.m. to 6:00 p.m.” “ Specifically, during PI, five new registered nurses were hired, as were three new medical support assistants (clerks), which increased nurse and clerk coverage by approximately 7% and 15%, respectively. No ED operations or staffing changes occurred between P2 and P3, other than the addition of TNT.”
leraci, 2008^18^ | “To accommodate the change, the ED was remodelled to provide a suitable area containing three examination trolleys, four reclining treatment chairs, a treatment room and a staff station. The net result of the remodelling was a reduction in the total number of treatment spaces (beds plus chairs) from 25 to 24.” “Separate clinical resources were provided to staff the FT area with two nurses round the clock, and one senior doctor (career medical officer, CMO) for 16 h/day. The CMO were specifically recruited to work only in FT, and had the experience and ability to work rapidly and relatively independently. The seniority of the staffing was considered crucial to the intended function, and junior doctors were not rostered to the area (although they saw FT patients during the night shift). The nursing staff rotated from the general ED pool, but also included two nurse practitioners (NP) who worked solely in the FT area. These staff and space were quarantined for FT patients – there was strong pressure not to re-allocate these resources to other areas of the ED.”
Singer, 2008^19^ | “The third phase involved hiring seven personnel, at a laboratory technologist level, so that a new workstation could be covered 24 hours per day in the central laboratory, 7 days per week. It also involved the purchase of new analyzers, at a cost of about $46,000, and installation of a dedicated pneumatic tube, at a cost of about $150,000.”
Gerton, 2009^20^ | “The PIT provided additional coverage that replaced a triage nurse, but did not change the physician staffing of the ED.” “During PIT hrs, 11.5 RVUs more were billed on average than without PIT (384 vs. 373; 95% CI +/-41). With RVU estimated at $38.08, charges increased by $438 / 8hr shift. If PIT were 5 d/wk for 1 yr, increased billing would be $118,000. This would not offset the cost of a physician.”
Arya, 2010^21^ | “The scribe training program is 60 hours in length.” “ The RVU/hr increased by 0.18 (95% confidence interval [CI] = 0.04 to 0.32, p = 0.0067) units when the percentage of a shift for which a scribe was utilized increases by 10%” “If a physician in our department changed from 0% to 100% of the patients seen with a scribe, 0.8 additional patients per hour can be evaluated in a 10-hour shift, and 24 (2.4/hr) additional RVUs would be generated.” “Based on the 2008 Medicare RVU reimbursement rate of $38 for one RVU, a scribe being utilized to full capacity, resulting in an additional 2.4 RVUs/hr generated, could result in an additional 91 billed dollars per hour. Scribes at our institution are salaried at approximately $16–$19 per hour, so unless an institution collects less than 30% of their billed revenue, scribes may be expected to improve the financial “bottom line. A complete cost analysis should of course take into consideration the fixed costs of training, as well as the variable costs of salary and nonsalary benefits.”
Han, 2010^10^ | Physician triage was initiated on July 11, 2005, 7 days a week from 1:00 p.m. to 9:00 p.m. A dedicated board certified or board-eligible emergency physician initiated diagnostic evaluation and treatment of patients in the waiting room after the triage nurse performed his or her initial evaluation. The triage physician was an additional physician to the existing staffing model.
Fry, 2011^22^ | “The TENP role, in July 2006, commenced with the employment of 3 full time equivalent positions, which provided a TENP on duty for 15 h a day Monday– Sunday (eight o’clock am to eleven o’clock pm).” (TENP = Transitional Emergency Nurse Practitioner)
Imperato, 2012^23^ | Implementation of the PIT protocol required the addition of two full-time equivalent attending physicians, at a total cost of $490,000 in additional salary costs per year plus fringe benefits. The nurse and technician assigned to the PIT were reallocated from another part of the ED, so no additional nursing staffing cost was incurred. A portion of the cost may have been recouped by incremental revenue captured by reducing the LWBS rate, but this effect is likely to be modest given the already-low LWBS rate before the PIT implementation. An additional source of cost recuperation may have been from a reduction of diversion time.
Soremekun, 2012^9^,^24^ | “Three components of the financial impact of the physician triage were considered: revenue, operational costs, and capital expenditure. Two main revenue sources were identified from the physician triage system in our study. The first was an increase in ED functional capacity that allowed for the care of additional medium acuity patients. Before implementation of physician screening, the ED was at full capacity and unable to care for additional medium acuity patients without a decrease in the quality of care provided or an increase in percentage of patients who LWBS. Therefore, the accelerated disposition of patients performed under the ED physician screening program allowed for care of additional medium acuity patients (low-acuity patients were excluded from the study), effectively increasing ED bed capacity to provide care for additional patients. The second revenue source was an increase in percent billable because of the decrease in the LWBS rate. Given that actual unit charges and reimbursement rates for ED visits and inpatient admissions are considered to be proprietary at our institution and also unique to our institution given the health care market in our state, we used revenue assumptions that are more representative of the national averages and performed sensitivity analysis around these assumptions to demonstrate the range in value of this intervention. The following revenue assumptions were made to determine the revenue impact of discharged patients: (1) average charges of $1390 per patient, based on medical expenditure panel survey, and (2) 35% collection rate, based on rates used in other financial studies and medical expenditure panel survey. The direct costs of ED care for discharged patients, as a percentage of revenue, were assumed to be 35%. This level of direct cost is based on prior published reports. Given the low rates of admissions in the LWBS population, we assumed no margin contribution from the hospitalization of these patients. The admission rate of the other medium acuity patients was based on the observed rate at the study site. The financial contribution margin of these patients’ total hospital stay was based on published margin contribution of $1000 per admission via the ED. Annual ED volume growth was assumed to be 3%. Incremental operational costs associated with physician screening include employee and marginal costs of providing care to patients. During operation, physician triage in our center requires an additional nurse practitioner (NP) who is responsible for following up on test results, ordering subsequent treatments, discharge planning, and arranging for the transition of care to appropriate inpatient teams. In addition to the NP, our system requires an additional 4 registered nurses and 1 clinical assistant. Fully loaded fulltime employee rates including benefits were assumed to be physician, $120 per hour; NP, $60 per hour; registered nurses, $40 per hour; and clinical assistant, $20 per hour. Rates were based on national averages from the bureau of labor statistics. Full-time employee salary growth rate was assumed to be 3%. Our center’s screening program required construction of dedicated clinical examination spaces adjacent to the triage area to permit the screening physician to obtain a medical history in private and to perform an appropriate physical examination. These 4 clinical spaces are integral to the safe acceleration of disposition decisions for selected patients in our program. The required capital expenditure to create 4 screening rooms, 2 workspaces (one in screening and one in postscreening area), a postscreening internal waiting area, and the associated infrastructure required to monitor and deliver care was $1 200 000 and based on national average hospital construction cost of $188 per square footage. At the study site, there was no increase in the total square footage of the ED but rather remodeling of the waiting area. The 2 workspaces are 500 ft2 each and contained 5 workstations.The screening rooms are 100 ft2 each and contain a stretcher,vital sign machine, otoscope and ophthalmoscope, and adjacent sink. The number of rooms was determined based on modeling a LOS in each screening room for each screened patient occupying the room for 20 minutes. The postscreening area (internal waiting room for patients who have been screened by the MD) consists of a 4875 ft2 waiting room with space for 5 stretchers and 16 chairs. The postscreening area allows the emergency physician to safely accommodate patients in the ED who can wait in an observed internal waiting room, better preserving the monitored bed spaces for those who truly need them. The postscreening area has equipment that allows for reassessment of vital signs, phlebotomy, and medication administration with a dedicatedmedication dispensing medicine for the nurses. Thedepreciation period was assumed to be 5 years. Time to set up physician screening was 12 months. In our financial model: cash flow (CF) = ED revenue -ED direct costs – operational costs of screening + inpatient margin contribution of admitted patients – capital expenditure. Return on investment (ROI) was calculated based on net present value (NPV) of a 5-year CF stream with no terminal value and a discount rate of 5%. The internal rate of return and years to break even were also calculated. Because multiple assumptions were made to estimate revenue and expenses, a detailed sensitivity analysis was performed to determine the impact of these assumptions on the ROI.”…. “The incremental revenue and operational expense projection generated from physician screening using aforementioned assumptions are depicted in Table 4. In year 1, the estimated ED contribution margin from discharged patients is $1 324 338 (growth in medium acuity patients, $1 137 234; LWBS patients, $187 104) and the estimated contribution margin from admitted patients is $1 384 718. The estimated operational expense associated with the physician screening system at year 1 is $1 864 104 ($1 624 104 in salary costs; $240 000 in depreciation costs). The total earnings and CF projection at year 1 are $844 952 and $1 084 952, respectively. Based on the CF projections and a discount rate of 5%, the NPV of physician screening was $2 816 263 and the internal rate of return is 85%, with time to break even of 13 months.”
Soremekun, 2014^25^ | “A dedicated midtrack area was fully implemented in January 2012 after the pilot period in December 2011. The area included three dedicated examination rooms and three hallway spaces. The fast-track area previously used this space, thus the implementation of the midtrack area reduced the dedicated fast-track area with no change in the overall number of treatment spaces in the study center. An attending physician who was reassigned from the main ED staffed the midtrack area so the total number of attending hours per day was also unchanged. The midtrack area, however, was staffed with two additional registered nurses (RNs) for an additional 16 hours or a 3.4% increase in total nursing clinical hours per day.”
Inokuchi, 2015^26^ | “We built the EMR system with a focus on clinical documentation using FileMaker. If a personal computer and wireless environment are available for the FileMaker server, the overall costs are low. Even including several iPads, printers, and scanners, the system can be built for less than 5000 US dollars, and it can easily be connected to the readymade EMR with a cable. In addition, emergency medical care varies depending on the hospital, thus EMR needs will also vary.”