# APPENDIX E Citations of Full Text Excludes

## Pre-1996 (n=3)

1 Tsai WW, Nash DB, Seamonds B, Weir GJ. Point-of-care versus central laboratory testing: an economic analysis in an academic medical center. Clin Ther. 1994;16(5):898–910; discussion 854.7859247
2 Stiell IGG, G.; McKnight, R.D.; Snell, C.C.; McDowell, I.; Nair, R.C.; Aubin, R. Triage nurse use of decision rules for radiography in ankle injuries. Ann Emerg Med. 1993;22:948.
3 Bliss AD, L.; Sauthwick, W. O. The emergency room nurse orders x-rays of distal limbs in orthopedic trauma. Nursing research. 1971;20(5):440–443.5208363

## Not Outcome of Interest (n=22)

1 Rydman RJ, Roberts RR, Albrecht GL, Zalenski RJ, McDermott M. Patient satisfaction with an emergency department asthma observation unit. Acad Emerg Med. 1999;6(3):178–183.10192667
2 Rydman RJ, Isola ML, Roberts RR, Emergency Department Observation Unit versus hospital inpatient care for a chronic asthmatic population: a randomized trial of health status outcome and cost. Med Care. 1998;36(4):599–609.9544599
3 Muntlin A, Carlsson M, Safwenberg U, Gunningberg L. Outcomes of a nurse-initiated intravenous analgesic protocol for abdominal pain in an emergency department: A quasi-experimental study. Int J Nurs Stud. 2011;48(1):13–23.20598691
4 McDermott MF, Murphy DG, Zalenski RJ, A comparison between emergency diagnostic and treatment unit and inpatient care in the management of acute asthma. Arch Intern Med. 1997;157(18):2055–2062.9382660
5 Hwang TG, Lee Y, Shin H. Structure-oriented versus process-oriented approach to enhance efficiency for emergency room operations: what lessons can we learn? Journal of healthcare management / American College of Healthcare Executives. 2011;56(4):255–267; discussion 267–258.21838024
6 Decker WW, Smars PA, Vaidyanathan L, A prospective, randomized trial of an emergency department observation unit for acute onset atrial fibrillation. Ann Emerg Med. 2008;52(4):322–328.18339449
7 van der Linden C, Reijnen R, de Vos R. Diagnostic accuracy of emergency nurse practitioners versus physicians related to minor illnesses and injuries. J Emerg Nurs. 2010;36(4):311–316.20624563
8 Shrimpling M. Redesigning triage to reduce waiting times. Emerg Nurse. 2002;10(2):34–37.
9 Rydman RJ, Zalenski RJ, Roberts RR, Patient satisfaction with an emergency department chest pain observation unit. Ann Emerg Med. 1997;29(1):109–115.8998089
10 Jennings N, Lee G, Chao K, Keating S. A survey of patient satisfaction in a metropolitan Emergency Department: comparing nurse practitioners and emergency physicians. Int J Nurs Pract. 2009;15(3):213–218.19531080
11 Imperato JM, S.; Sanchez, D, Setnik, G. Improving patient satisfaction by adding a physician in triage. J Hosp Adm. 2013;3(1):7–13.
12 Fry M. Triage nurses order x-rays for patients with isolated distal limb injuries: A 12-month ED study. J Emerg Nurs. 2001;27(1):17–22.11174265
13 Chan TCK, J.P.; Kelly, D.L.; Vilke, G.M.; Guss, D.A. Accellerated care at triage: physician-directed ancillary testing at triage for patients waiting in an emergency department. Ann Emerg Med. 2005;46:S107.
14 Roberts RR, Zalenski RJ, Mensah EK, Costs of an emergency department-based accelerated diagnostic protocol vs hospitalization in patients with chest pain: a randomized controlled trial. JAMA. 1997;278(20):1670–1676.9388086
15 Miller CD, Hwang W, Hoekstra JW, Stress cardiac magnetic resonance imaging with observation unit care reduces cost for patients with emergent chest pain: a randomized trial. Ann Emerg Med. 2010;56(3):209–219 e202.20554078
16 Miller CD, Hwang W, Case D, Stress CMR imaging observation unit in the emergency department reduces 1-year medical care costs in patients with acute chest pain: a randomized study for comparison with inpatient care. JACC Cardiovasc Imaging. 2011;4(8):862–870.21835378
17 Miller CD, Case LD, Little WC, Stress CMR reduces revascularization, hospital readmission, and recurrent cardiac testing in intermediate-risk patients with acute chest pain. JACC Cardiovasc Imaging. 2013;6(7):785–794.23664718
18 McClellan CM, Cramp F, Powell J, Benger JR. A randomised trial comparing the clinical effectiveness of different emergency department healthcare professionals in soft tissue injury management. BMJ Open. 2012;2(6).
19 Dinh M, Walker A, Parameswaran A, Enright N. Evaluating the quality of care delivered by an emergency department fast track unit with both nurse practitioners and doctors. Australas Emerg Nurs J. 2012;15(4):188–194.23217651
20 McNeill GB, Brand C, Clark K, Optimizing care for acute medical patients: the Australasian Medical Assessment Unit Survey. Intern Med J. 2011;41(1a):19–26.21040322
21 Lo SM, Choi KT, Wong EM, Effectiveness of Emergency Medicine Wards in reducing length of stay and overcrowding in emergency departments. Int Emerg Nurs. 2014;22(2):116–120.24080095
22 Tseng JC, Li CH, Chen KF, Outcomes of an emergency department intensive care unit in a tertiary medical center in Taiwan: An observational study. Journal of critical care. 2015;30(3):444–448.25660907

## No Intervention (n=3)

1 Yoon P, Steiner I, Reinhardt G. Analysis of factors influencing length of stay in the emergency department. CJEM. 2003;5(3):155–161.17472779
2 Considine J, Martin R, Smit D, Jenkins J, Winter C. Defining the scope of practice of the emergency nurse practitioner role in a metropolitan emergency department. Int J Nurs Pract. 2006;12(4):205–213.16834581
3 Mandirola Brieux HF, Guillen S, La Rosa F, Moreno C, Benitez S. Nursing Software for Emergency Triage (NSET). Studies in health technology and informatics. 2015;216:942.26262244

## Not ED Study (n=2)

1 Koshy S, Feustel PJ, Hong M, Kogan BA. Scribes in an ambulatory urology practice: patient and physician satisfaction. J Urol. 2010;184(1):258–262.20483153
2 Bank AJ, Obetz C, Konrardy A, Impact of scribes on patient interaction, productivity, and revenue in a cardiology clinic: a prospective study. Clinicoecon Outcomes Res. 2013;5:399–406.23966799

## Systematic Review (n=3)

1 Wilson A, Zwart E, Everett I, Kernick J. The clinical effectiveness of nurse practitioners’ management of minor injuries in an adult emergency department: a systematic review. Int J Evid Based Healthc. 2009;7(1):3–14.21631842
2 Scott I, Vaughan L, Bell D. Effectiveness of acute medical units in hospitals: a systematic review. Int J Qual Health Care. 2009;21(6):397–407.19903756
3 Carter AJ, Chochinov AH. A systematic review of the impact of nurse practitioners on cost, quality of care, satisfaction and wait times in the emergency department. CJEM. 2007;9(4):286–295.17626694

## Not Available (n=2)

1 Winn K. Emergency Department Efficiency Through Utilization of Triage Nurse Protocols. Texas, Texas Tech University Health Science Center; 2001.
2 Ching KL, L.; See, N. B. Initiation of x-rays by the triage nurse: competency and its effect on patient’s total time spent in the A & E department. Singapore Nursing Journal. 1999;26(3):22–26.

## Duplicate (n=1)

1 McClellan CM, Cramp F, Powell J, Benger JR. A randomised trial comparing the cost effectiveness of different emergency department healthcare professionals in soft tissue injury management. BMJ Open. 2013;3(1).