# APPENDIX D Citations of Included Publications

1 Allen B BB, Weeks E, Payton T. An Assessment of Emergency Department Throughput and Provider Satisfaction after the Implementation of a Scribe Program. Advances in Emergency Medicine. 2014;2014(1).
2 Ardagh MW, Wells JE, Cooper K, Lyons R, Patterson R, O’Donovan P. Effect of a rapid assessment clinic on the waiting time to be seen by a doctor and the time spent in the department, for patients presenting to an urban emergency department: a controlled prospective trial. N Z Med J. 2002;115(1157):U28.12362191
3 Arya R, Salovich DM, Ohman-Strickland P, Merlin MA. Impact of scribes on performance indicators in the emergency department. Acad Emerg Med. 2010;17(5):490–494.20536801
4 Asha SE, Ajami A. Improvement in emergency department length of stay using an early senior medical assessment and streaming model of care: A cohort study. Emerg Med Australas. 2013;25(5):445–451.24099374
5 Asha SE, Chan AC, Walter E, Impact from point-of-care devices on emergency department patient processing times compared with central laboratory testing of blood samples: a randomised controlled trial and cost-effectiveness analysis. Emerg Med J. 2014;31(9):714–719.23748157
6 Bastani A, Shaqiri B, Palomba K, Bananno D, Anderson W. An ED scribe program is able to improve throughput time and patient satisfaction. Am J Emerg Med. 2014;32(5):399–402.24637134
7 Baumann MRS, T.D.; Moddy, J.L. Institute for health care improvement impact collaborative; team triage and treatment in the emergency department. Acad Emerg Med. 2006;13(5):S129.
8 Bond PA. A staffed ED assessment room: impact on wait times for nonurgent patients at a Saudi Arabian hospital. J Emerg Nurs. 2001;27(4):394–395.11468636
9 Bullard ML, A.; Latoszek, K.; Holroyd, B.; Rowe, B. Impact of a rapid-assessment pod on ED overcrowding measures: a randomized trial. Acad Emerg Med. 2008;15(5 Supp 1):S197.
10 Burstrom L, Nordberg M, Ornung G, Physician-led team triage based on lean principles may be superior for efficiency and quality? A comparison of three emergency departments with different triage models. Scand J Trauma Resusc Emerg Med. 2012;20:57.22905993
11 Byrne G, Richardson M, Brunsdon J, Patel A. An evaluation of the care of patients with minor injuries in emergency settings. Accid Emerg Nurs. 2000;8(2):101–109.10818377
12 Chan TC, Killeen JP, Kelly D, Guss DA. Impact of rapid entry and accelerated care at triage on reducing emergency department patient wait times, lengths of stay, and rate of left without being seen. Ann Emerg Med. 2005;46(6):491–497.16308060
13 Cheng I, Lee J, Mittmann N, Implementing wait-time reductions under Ontario government benchmarks (Pay-for-Results): a Cluster Randomized Trial of the Effect of a Physician-Nurse Supplementary Triage Assistance team (MDRNSTAT) on emergency department patient wait times. BMC emergency medicine. 2013;13:17.24207160
14 Cheung WW, Heeney L, Pound JL. An advance triage system. Accid Emerg Nurs. 2002;10(1):10–16.11998578
15 Choi YF, Wong TW, Lau CC. Triage rapid initial assessment by doctor (TRIAD) improves waiting time and processing time of the emergency department. Emerg Med J. 2006;23(4):262–265; discussion 262–265.16549569
16 Colligan M, Collins C, Foley B, Jones P, Miles J, Zeng I. Emergency nurse practitioners: do they provide an effective service in managing minor injuries, compared to emergency medicine registrars? N Z Med J. 2011;124(1344):74–80.
17 Considine J, Kropman M, Kelly E, Winter C. Effect of emergency department fast track on emergency department length of stay: a case-control study. Emerg Med J. 2008;25(12):815–819.19033498
18 Considine J, Martin R, Smit D, Winter C, Jenkins J. Emergency nurse practitioner care and emergency department patient flow: case-control study. Emerg Med Australas. 2006;18(4):385–390.16842309
19 Considine JK, M.; Stergiou, H. E. Effect of clinician designation on emergency department fast track performance. Emergency Medicine Journal. 2010;27(11):838–842.20581389
20 Cooke MW, Wilson S, Pearson S. The effect of a separate stream for minor injuries on accident and emergency department waiting times. Emerg Med J. 2002;19(1):28–30.11777867
21 Crane PS, S. Effect of a triage doctor on length of stay in a crowded urban emergency department. Acad Emerg Med. 2009;16(4):S271.
22 Crane WY, B.; Schneider, M. Avlack of effect on patient satisfaction scores in one large urban emergency department Int J Clin Med. 2012;3(7a):740–743.
23 Darrab AA, Fan J, Fernandes CM, How does fast track affect quality of care in the emergency department? Eur J Emerg Med. 2006;13(1):32–35.16374246
24 Davis RA, Dinh MM, Bein KJ, Veillard AS, Green TC. Senior work-up assessment and treatment team in an emergency department: a randomised control trial. Emerg Med Australas. 2014;26(4):343–349.24935075
25 Day TE, Al-Roubaie AR, Goldlust EJ. Decreased length of stay after addition of healthcare provider in emergency department triage: a comparison between computer-simulated and real-world interventions. Emerg Med J. 2013;30(2):134–138.22398851
26 Ducharme J, Alder RJ, Pelletier C, Murray D, Tepper J. The impact on patient flow after the integration of nurse practitioners and physician assistants in 6 Ontario emergency departments. CJEM. 2009;11(5):455–461.19788790
27 Fan J, Woolfrey K. The effect of triage-applied Ottawa Ankle Rules on the length of stay in a Canadian urgent care department: a randomized controlled trial. Acad Emerg Med. 2006;13(2):153–157.16436790
28 Fernandes CM, Christenson JM, Price A. Continuous quality improvement reduces length of stay for fast-track patients in an emergency department. Acad Emerg Med. 1996;3(3):258–263.8673783
29 French S, Lindo JL, Williams Jean EW, Williams-Johnson J. Doctor at triage - effect on waiting time and patient satisfaction in a Jamaican hospital. Int Emerg Nurs. 2014;22(3):123–126.24149092
30 Fry MF, J.; Asha, S.; Arendts, G. A 12-month evaluation of the impact of Transitional Emergency Nurse Practitioners in one metropolitan Emergency Department. Australasian Emergency Nursing Journal. 2011;14(1):4–8.
31 Fry MJ, K. The clinical initiative nurse: extending the role of the emergency nurse, who benefits? Australasian Emergency Nursing Journal. 2005;8(1):9–12.
32 Gerton JS, E.; Pimentel, L.; Ercolano, P.; Browne, B.; Barrueto, F. When is a physician in triage a financially viable option? Acad Emerg Med. 2009;16(4):S272.
33 Graham CAM, C.Y.; Shum, K.; Tang, C.O.; Rainer, T.H. Senior medical presence at triage improves service time in emergency departments. Emerg Med Australas. 2009;21:A26.
34 Grant SS, D.; Green, D. Rapid assessment team reduces waiting time. Emerg Med Australas. 1999;11(2):72–77.
35 Gray SHK, S.J.; Spence, J.M. Does having an emergency physician at triage for a 4-hour shift reduce ED length of stay? CJEM. 2009;11:272.
36 Han JH, France DJ, Levin SR, Jones ID, Storrow AB, Aronsky D. The effect of physician triage on emergency department length of stay. J Emerg Med. 2010;39(2):227–233.19168306
37 Holroyd BR, Bullard MJ, Latoszek K, Impact of a triage liaison physician on emergency department overcrowding and throughput: a randomized controlled trial. Acad Emerg Med. 2007;14(8):702–708.17656607
38 Ieraci S, Digiusto E, Sonntag P, Dann L, Fox D. Streaming by case complexity: evaluation of a model for emergency department Fast Track. Emerg Med Australas. 2008;20(3):241–249.18462407
39 Imperato J, Morris DS, Binder D, Physician in triage improves emergency department patient throughput. Intern Emerg Med. 2012;7(5):457–462.22865230
40 Inokuchi R, Sato H, Iwagami M, Impact of a New Medical Record System for Emergency Departments Designed to Accelerate Clinical Documentation: A Crossover Study. Medicine. 2015;94(26):e856.26131837
41 Jennings N, O’Reilly G, Lee G, Cameron P, Free B, Bailey M. Evaluating outcomes of the emergency nurse practitioner role in a major urban emergency department, Melbourne, Australia. J Clin Nurs. 2008;17(8):1044–1050.18321270
42 Kelly AM, Bryant M, Cox L, Jolley D. Improving emergency department efficiency by patient streaming to outcomes-based teams. Aust Health Rev. 2007;31(1):16–21.17266484
43 Kendall J, Reeves B, Clancy M. Point of care testing: randomised controlled trial of clinical outcome. BMJ. 1998;316(7137):1052–1057.9552905
44 Keyes DC, Singal B, Kropf CW, Fisk A. Impact of a new senior emergency department on emergency department recidivism, rate of hospital admission, and hospital length of stay. Ann Emerg Med. 2014;63(5):517–524.24342817
45 Kilic YA, Agalar FA, Kunt M, Cakmakci M. Prospective, double-blind, comparative fast-tracking trial in an academic emergency department during a period of limited resources. Eur J Emerg Med. 1998;5(4):403–406.9919444
46 Kim MJ, Park JM, Je SM, Effects of a short text message reminder system on emergency department length of stay. International journal of medical informatics. 2012;81(5):296–302.22300639
47 King DL, Ben-Tovim DI, Bassham J. Redesigning emergency department patient flows: application of Lean Thinking to health care. Emerg Med Australas. 2006;18(4):391–397.16842310
48 Kwa P, Blake D. Fast track: has it changed patient care in the emergency department? Emerg Med Australas. 2008;20(1):10–15.17999686
49 Lee KM, Wong TW, Chan R, Lau CC, Fu YK, Fung KH. Accuracy and efficiency of X-ray requests initiated by triage nurses in an accident and emergency department. Accid Emerg Nurs. 1996;4(4):179–181.8981838
50 Lee-Lewandrowski E, Corboy D, Lewandrowski K, Sinclair J, McDermot S, Benzer TI. Implementation of a point-of-care satellite laboratory in the emergency department of an academic medical center. Impact on test turnaround time and patient emergency department length of stay. Arch Pathol Lab Med. 2003;127(4):456–460.12683874
51 Levsky ME, Young SE, Masullo LN, Miller MA, Herold TJ. The effects of an accelerated triage and treatment protocol on left without being seen rates and wait times of urgent patients at a military emergency department. Mil Med. 2008;173(10):999–1003.19160619
52 Lindley-Jones M, Finlayson BJ. Triage nurse requested x rays--are they worthwhile? J Accid Emerg Med. 2000;17(2):103–107.10718230
53 Moloney ED, Bennett K, O’Riordan D, Silke B. Emergency department census of patients awaiting admission following reorganisation of an admissions process. Emerg Med J. 2006;23(5):363–367.16627837
54 Muntlin Athlin A, von Thiele Schwarz U, Farrohknia N. Effects of multidisciplinary teamwork on lead times and patient flow in the emergency department: a longitudinal interventional cohort study. Scand J Trauma Resusc Emerg Med. 2013;21:76.24180367
55 Murray RP, Leroux M, Sabga E, Palatnick W, Ludwig L. Effect of point of care testing on length of stay in an adult emergency department. J Emerg Med. 1999;17(5):811–814.10499694
56 Murrel KO, S.; Carl, M.; Kauffman, M.; Loeffler, R. Implementation of an emergency department physician triage system decreases patient wait times and “left without being seen” rates. Acad Emerg Med. 2009;16(4):S204–S205.
57 Nash K, Zachariah B, Nitschmann J, Psencik B. Evaluation of the fast track unit of a university emergency department. J Emerg Nurs. 2007;33(1):14–20; quiz 90.17258047
58 O’Brien D, Williams A, Blondell K, Jelinek GA. Impact of streaming “fast track” emergency department patients. Aust Health Rev. 2006;30(4):525–532.17073548
59 Parris W, McCarthy S, Kelly AM, Richardson S. Do triage nurse-initiated X-rays for limb injuries reduce patient transit time? Accid Emerg Nurs. 1997;5(1):14–15.9069728
60 Partovi SN, Nelson BK, Bryan ED, Walsh MJ. Faculty triage shortens emergency department length of stay. Acad Emerg Med. 2001;8(10):990–995.11581086
61 Parvin CA, Lo SF, Deuser SM, Weaver LG, Lewis LM, Scott MG. Impact of point-of-care testing on patients’ length of stay in a large emergency department. Clin Chem. 1996;42(5):711–717.8653896
62 Patel H, Celenza A, Watters T. Effect of nurse initiated X-rays of the lower limb on patient transit time through the emergency department. Australas Emerg Nurs J. 2012;15(4):229–234.23217656
63 Patel PB, Combs MA, Vinson DR. Reduction of admit wait times: the effect of a leadership-based program. Acad Emerg Med. 2014;21(3):266–273.24628751
64 Patel PB, Vinson DR. Team assignment system: expediting emergency department care. Ann Emerg Med. 2005;46(6):499–506.16308063
65 Pedersen GB, Storm JO. [Emergency department X-rays requested by physicians or nurses]. Ugeskr Laeger. 2009;171(21):1747–1751.19454193
66 Penciner RE, A.; Paraghamian, G.; Richard, H.; Rutledge, T.; Woollard, S. Improving care of subacute patients in the emergency department: the Kaizen approach. CJEM. 2008;10(3):275.
67 Porter JB, D.; Parrish, G.; Papa, L.; Nickolenko, P.; Bullard, T. Resident triage-impact on patient satisfaction. Acad Emerg Med. 2009;16(4):S272.
68 Retezar R, Bessman E, Ding R, Zeger SL, McCarthy ML. The effect of triage diagnostic standing orders on emergency department treatment time. Ann Emerg Med. 2011;57(2):89–99 e82.20541284
69 Richardson JR, Braitberg G, Yeoh MJ. Multidisciplinary assessment at triage: a new way forward. Emerg Med Australas. 2004;16(1):41–46.15239754
70 Rodi SW, Grau MV, Orsini CM. Evaluation of a fast track unit: alignment of resources and demand results in improved satisfaction and decreased length of stay for emergency department patients. Qual Manag Health Care. 2006;15(3):163–170.16849988
71 Rogers T, Ross N, Spooner D. Evaluation of a ‘See and Treat’ pilot study introduced to an emergency department. Accid Emerg Nurs. 2004;12(1):24–27.14700568
72 Rogg JG, White BA, Biddinger PD, Chang Y, Brown DF. A long-term analysis of physician triage screening in the emergency department. Acad Emerg Med. 2013;20(4):374–380.23701345
73 Rosmulder RW, Krabbendam JJ, Kerkhoff AH, Schinkel ER, Beenen LF, Luitse JS. [‘Advanced triage’ improves patient flow in the emergency department without affecting the quality of care]. Ned Tijdschr Geneeskd. 2010;154:A1109.20356429
74 Ross MA, Hockenberry JM, Mutter R, Barrett M, Wheatley M, Pitts SR. Protocol-driven emergency department observation units offer savings, shorter stays, and reduced admissions. Health affairs. 2013;32(12):2149–2156.24301399
75 Ruoff BA, P.; Banet, G.; Williams, D.; Lewis, L. The effect of physician triage on elopement rates, throughput, and patient satisfaction. Acad Emerg Med. 2004;11:464.
76 Sakr M, Kendall R, Angus J, Sanders A, Nicholl J, Wardrope J. Emergency nurse practitioners: a three part study in clinical and cost effectiveness. Emerg Med J. 2003;20(2):158–163.12642530
77 Sanchez M, Smally AJ, Grant RJ, Jacobs LM. Effects of a fast-track area on emergency department performance. J Emerg Med. 2006;31(1):117–120.16798173
78 Schlicher NP, T.; Long, H.; Rutschilling, J. Physician in triage improves patient treatment times over nurse-initiated protocols for all acuity levels. Acad Emerg Med. 2009;16(4):S271.
79 Schull MJ, Vermeulen MJ, Stukel TA, Evaluating the effect of clinical decision units on patient flow in seven Canadian emergency departments. Acad Emerg Med. 2012;19(7):828–836.22805630
80 Shetty A, Gunja N, Byth K, Vukasovic M. Senior Streaming Assessment Further Evaluation after Triage zone: a novel model of care encompassing various emergency department throughput measures. Emerg Med Australas. 2012;24(4):374–382.22862754
81 Sigal BN, C.; Gibson, H.; Hodder, G.; Singal, B.; Palmisano, T.; Mikhail, M. A mid-level provider after triage to reduce patients who left without being seen. Emerg Med Australas. 2007;14(5):S209.
82 Singer AJ, Viccellio P, Thode HC, Jr., Bock JL, Henry MC. Introduction of a stat laboratory reduces emergency department length of stay. Acad Emerg Med. 2008;15(4):324–328.18370985
83 Soremekun OA, Biddinger PD, White BA, Operational and financial impact of physician screening in the ED. Am J Emerg Med. 2012;30(4):532–539.21419587
84 Soremekun OA, Capp R, Biddinger PD, Impact of physician screening in the emergency department on patient flow. J Emerg Med. 2012;43(3):509–515.22445677
85 Soremekun OA, Shofer FS, Grasso D, Mills AM, Moore J, Datner EM. The effect of an emergency department dedicated midtrack area on patient flow. Acad Emerg Med. 2014;21(4):434–439.24730406
86 Spalding SC, Mayer PH, Ginde AA, Lowenstein SR, Yaron M. Impact of computerized physician order entry on ED patient length of stay. Am J Emerg Med. 2011;29(2):207–211.20825803
87 Steiner IP, Nichols DN, Blitz S, Impact of a nurse practitioner on patient care in a Canadian emergency department. CJEM. 2009;11(3):207–214.19523269
88 Storm-Versloot MN, Vermeulen H, van Lammeren N, Luitse JS, Goslings JC. Influence of the Manchester triage system on waiting time, treatment time, length of stay and patient satisfaction; a before and after study. Emerg Med J. 2014;31(1):13–18.23302504
89 Subash F, Dunn F, McNicholl B, Marlow J. Team triage improves emergency department efficiency. Emerg Med J. 2004;21(5):542–544.15333524
90 Svirsky I, Stoneking LR, Grall K, Berkman M, Stolz U, Shirazi F. Resident-initiated advanced triage effect on emergency department patient flow. J Emerg Med. 2013;45(5):746–751.23777776
91 Terris J, Leman P, O’Connor N, Wood R. Making an IMPACT on emergency department flow: improving patient processing assisted by consultant at triage. Emerg Med J. 2004;21(5):537–541.15333523
92 Thurston J, Field S. Should accident and emergency nurses request radiographs? Results of a multicentre evaluation. J Accid Emerg Med. 1996;13(2):86–89.8653256
93 Traub SJ, Stewart CF, Didehban R, Emergency Department Rotational Patient Assignment. Ann Emerg Med. 2016;67(2):206–215.26452721
94 Travers JP, Lee FC. Avoiding prolonged waiting time during busy periods in the emergency department: Is there a role for the senior emergency physician in triage? Eur J Emerg Med. 2006;13(6):342–348.17091056
95 Welch S, Dalto J. Improving door-to-physician times in 2 community hospital emergency departments. American journal of medical quality: the official journal of the American College of Medical Quality. 2011;26(2):138–144.21212447
96 White BA, Brown DF, Sinclair J, Supplemented Triage and Rapid Treatment (START) improves performance measures in the emergency department. J Emerg Med. 2012;42(3):322–328.20554420
97 Wu KH, Cheng FJ, Li CJ, Cheng HH, Lee WH, Lee CW. Evaluation of the effectiveness of peer pressure to change disposition decisions and patient throughput by emergency physician. Am J Emerg Med. 2013;31(3):535–539.23347714