# APPENDIX C Peer Review Comments/Author Responses

Comment | Response
Definitions – Including definitions of key terms, such as “ED efficiency” and “evidence” would help make the paper’s contributions more clear and concise. These terms are often used without us being absolutely certain what they mean. For example, in the manuscript, length-of-stay (LOS) is cited as a core efficiency metric. Why is that? Efficiency is typically defined as the amount of output produced relative to the inputs consumed. Length-of-stay says nothing about either of these. An operationally “efficient” ED (i.e., one that serves many patients well at a low operating cost) could have a longer LOS due solely to having sicker patients or a lack of consulting resources from the larger hospital, which can delay disposition while not saying anything about the “efficiency” of the ED. Perhaps “operational performance” would be a better term than “efficiency” if accuracy is valued. | We have updated our introduction to better discuss the term “ED efficiency” as it is used for our report. We agree that efficiency is a ratio of output to input, and to convey this ratio we have presented the core metrics you describe with the categorizations of inputs in the maps. While we describe the input and output data separately in this report, the intent of the maps is to visually integrate the two parts of the ratio to start to describe the distribution of evidence (i.e., where there is evidence of potential efficiency vs where less evidence exists). We disagree that LOS says nothing about the amount of output. An airplane flight that is direct and takes 4 hours in one plane, and another flight that requires a 2 hour layover with total transit time of 6 hours both get one traveler to the same destination in a safe manner, but the former is considered by most travelers and workers to be a more efficient means than the latter to get from point A to point B. Typically these efficiency interventions are implemented in overcrowded EDs with an appreciable percentage of patients who leave without being seen, We agree that LOS is not a very good measure of outputs, since there is no assessment of the quality of the output. We can’t switch to “operational performance” because the title was given to us by VA policymakers. What we consider to be evidence is described in the “Inclusion/Exclusion Criteria” subsection of the methods, and we have more formally introduced the term evidence now.
Definitions: Did these studies routinely and clearly define each of the measures they used? In addition, measures of variability (SD, IQR) may be useful to include in reporting results. | The included publications varied both in the extent to which they provided definitions for the outcome measures they used, and how they measured outcomes when this way reported. Both the definitions and the measures of variability would be important data to gather in a formal systematic review of some piece of this overarching evidence map, but would require detailed reading of each included article/study that goes beyond the scope of the data abstraction for an evidence map. These points are now raised in the discussion.
Survivor Bias – The collection of papers used to generate the “evidence maps” suffers from survivor bias in that they were all successfully published. We know that journals favor studies that have positive results (vs. those that find policy X had no effect). It would be like, for example, a therapeutic efficacy study that tossed out the data from every patient who died before the final reporting period. Therefore, the validity of this manuscript is somewhat suspect and likely overstates the improvements garnered by the various interventions. However, since we cannot know what isn’t published, there isn’t an ideal strategy for dealing with this problem, but it should be acknowledged in the report as a significant limitation. | Thank you for pointing out this important omission, we have now included a description of the publication bias issue you raise here. Note that the existence of publication bias on the basis of results (positive results being more likely to get published) is a matter of controversy with respect to it being the fault of journals. Kay Dickersin has done extensive work in this area and concluded that in one of the most careful assessments of this ever done, and concluded that to a large extent the lack of publication of negative studies is because the investigators lost interest in it and never submitted the results to a journal.
Categories – On page 4, the paper says it “…ordered these [intervention] categories according to their usefulness to ED leaders…” How does the research team know this? Moreover, the categories are treated as mutually exclusive, but actually have the potential to overlap. The categories are “quantified description of resource expenditures,” “reallocation of resources,” “addition of resources,” and “unclear.” Isn’t it possible for an ED to expend resources during the reallocation of resources (e.g., mroe scheduling effort, cross-training, etc.)? Or, more clearly, if a facility adds resources and quantifies them, shouldn’t it be in both categories? This categorization seems somewhat arbitrary and, because it is highly unlikely to be generalizable from one facility to another, largely unhelpful. Despite those limitations, it is used in every “evidence map” (via bubble colors), suggesting that some other dimension (e.g., improvement range) might be a better choice. | We agree, and have updated our categories and removed the phrase to which you refer. The categories are now mutually exclusive, and in combination with other peer reviewer comments, this new categorization addresses the issues raised.
Improvement Concepts – There is little effort in this manuscript to extract from the original papers the thinking behind the interventions that were tested. What underlying concept was being drawn upon to motivate a facility to implement a fast track or to put an MD in triage? Were they all the same? Or did they arrive at those interventions from different lines of thinking? Until we understand WHY an intervention is expected to improve the operational performance of an ED, we cannot make a good guess as to whether or not it makes sense in any particular ED’s context. This may be criticized as being too theoretical, but theory is what makes modern medicine work…should expect anything less for how we manage our EDs? | This is an important consideration, and this type of detailed analysis would be important work for a formal systematic review of some piece of this overarching evidence map, but would require a more detailed analysis of individual publications than provided by the scope of an evidence map. Our goal was to map the extent of research in a broad topic, and these next questions would be a natural extension to our preliminary work. This point is now raised in the future work section of the report.
Minor issue – On page 10, it says “Physician triage was the most commonly studied intervention, and the one with the most studies where costs were quantified.” That second phrase is true because of the first phrase – even small percentages of large numbers can result in large numbers. Perhaps it would be more useful to look at which types of interventions had the highest _proportions_ of different categories (assuming these categories are useful in the first place, which is suspect). | We have updated this phrasing and our categories.
Lit Stats – A significant portion of the manuscript is statistics about the literature gathered by the team (e.g., Map 1 ), which do not actually do much to help ED managers make decisions about how to operate more effectively and efficiently. Pages 10-17 do not seem to contribute substantially to the mission of the report. | We think there is a misunderstanding of the goal of the report. The goal is not to report a detailed analysis of the evidence of one or more ED interventions. The goal was to create an evidence map that quantifies this corpus of literature by a few categorical variables. As such, these maps are intended to show the work that has been done in a snapshot across a broad set of work, and are not intended to do a more detailed analysis of the interventions identified. Future work would be necessary to address this question. We have removed the set of maps with raw change values (eg, wait time in minutes) to reduce the amount of data and focus on the more salient points
Summarize & Synthesize – Could the 2-page excerpt from Soremekum (2012) on pages 15-17 be condensed somehow? This seems like a lot to read for relatively little benefit (vis-a-vis the report’s objectives). | We agree, and have updated/abridged this table and put the full contents in an appendix.
Scope – Limiting the scope of the document to only those papers that have implemented interventions leaves a large amount of evidence out of consideration, to the study’s (and the VA’s) detriment. For example, the one study cited in this manuscript that was carried out in a VA ED found that discrete-event simulation accurately predicted the operational improvements that were realized when the new policy was actually implemented. Not every policy can be implemented, even if the simulation or modeling suggests it would help significantly. Ignoring those papers in a summary of “the evidence” will only perpetuate the “disconnect between theory and practice” cited in this manuscript (page 24). Moreover, as many EDs are in fact “resource-poor environments” (page 2), the ability to model new policies to estimate their impact on practice becomes even more important. | The inclusion criterion of requiring that an intervention was applied in an ED (thereby rejecting simulation studies) was made at the direction of our operational partners and technical experts. Reviewing such studies would need to be the focus of some future review. We have revised our discussion of simulation studies in the limitations to include your point.
Usefulness – The “evidence maps” on pages 18-22 do not seem to yield many useful conclusions about what changes ED managers should make to how their EDs operate. These maps are not an adequate substitute for an actual meta-analysis (as mentioned in the limitations on page 24) or other analyses that might extract out some clear insights. For example, looking at Map 2 on page 18, what should the take-away be for an ED manager? I honestly can’t tell. Perhaps it would be better to pull out each type of intervention (e.g., MD in triage) and then produce a graph that has an improvement metric on one axis and resource use (or a contrasting improvement metric) on the other. Different studies would have different positions in that graph, yielding insights related to questions like “Does greater expense tend to produce greater improvements?” and “Are these two performance outcomes trade-offs or are they complementary?” That would be substantially more useful to VAs than these plots, yet could be generated using the same data presented in these maps. | We agree that these maps are not serving the same purpose as metaanalyses, and our intention is to highlight the types of ED efficiency work that has been done, and identify areas where future research may be needed. This map was requested for the VA Emergency Medicine Field Advisory Committee field-based meeting “Toward a VA Emergency Medicine Research Agenda: Setting Priorities to Improve the Health of Veterans Seeking Emergency Care.” We have added this to our topic development section to better describe our scope.
ED overcrowding is mentioned prominently in the report. Were any studies encountered that measured facility level ED census outcomes; eg, proportion of time above capacity? If there was a decision to focus on patient-level outcomes, which would make sense, would be useful to state this. | We did not capture this data, as we focused on the six outcomes listed in the Study Selection Criteria appendix.
I appreciate the focus on resource reporting as I do think it’s an important point. However I think the data presentation in Table 2 could be misleading. It seems to me that almost all (maybe all? Defer to authors on this point) of papers that quantify costs, are describing additional resources. It seems to the 3 main groups to readers are 1) Adds Resources; 2) Reallocated Resources; 3) Not enough information to classify. The Costs quantified vs. qualitatively described seem like subcategories. It may be more informative to report as:; Adds New Resources; - Cost quantified; - Cost qualitatively described; Reallocated Resources; - Cost quantified (if there are any in this category); - Cost qualitatively described; Unclear | We have simplified our categorizations to align with your suggestions, and rather than add sub-categories that may be confusing in such a rich data presentation, we have discussed this separately.
Can you say more about the comparison conditions for the observational studies? Were these all pre-post designs, or did any use external or contemporaneous controls? | We have added information on study design to our report.
Methods: Lines 40-41. Studies had to include LOS, WT, OR LWBS? At this stage of paper I was unclear as to whether the requirement was for ALL or ANY of these to be reported for inclusion. It’s clear in the Abstract but less so here. | The “and” in the phrasing has been changed to an “or” for greater clarity. We required ANY outcome, not ALL.
Line 48. Studies that did not in any way describe the resources expended were excluded but in Results section there is no mention of studies being excluded on this basis. Is this correct that no studies were excluded on this basis? | This text was incorrect, and has been updated, since no studies were excluded on this basis.
Line 54. Agree with exclusion of modeling and simulation studies; not sure what is meant by “theoretical interventions” | This section has been re-written, and the language about “theoretical interventions” has been removed.
Effect on LOS by intervention type: lines 10-12 No Medical Scribe studies reported positive effects or measured this outcome at all? | No medical scribe studies measured this outcome, text has been updated to clarify this point.
Search strategy tables have some terms like ‘patient satisfaction’. Was this dropped or no relevant studies identified? | We decided not to abstract information on this outcome, and chose to focus on the six outcomes listed in our Study Selection Criteria appendix.
Suggest more discussion of the recommendations around measurement. In the Summary and Discussion section I’m not sure what is meant by saying the Doupe paper recommends reporting ‘all necessary metrics..” do you mean the efficiency metrics you’ve measured here? I would imagine there are cautions here around also whether studies reporting relatively rare outcomes like LWBS or continuous metrics that may have distributional challenges due to outliers, etc. are adequately powered. | The discussion section has been reworded, and we have incorporated your cautions as an important consideration for future work in this area.
p.4 para 1 line 5: I find it surprising that you were able to consistently define LOS as “bed assignment to final disposition” as this is not routinely available. Typically, LOS is arrival-to-exit. Please verify that this is correct as I am suspicious that it is not. Looking at the outcomes reported on p. 8, I’m surprised that 69% would meet this definition of LOS further reinforcing the need to verify this. | We were not able to have a consistent definition, but rather used these definitions to guide our data analysis when multiple data points were available. This text has been updated to reflect this. We also discuss the issue of defining measure in more detail in our limitations section.
p.4 para 1 line 10: Clarify the definition of LWBS. When referring to “all visits” do you mean for the day? | This was not well defined in the studies, but typically reflected the percentage of patients who left before being seen of all patients over the study period. This language has been updated for clarity.
p.7 Figure 1: I suspect that many of these interventions were overlapping in categories. How did you handle overlapping interventions? | This was a conceptual challenge for our team, but in order to have one bubble per study (mutually exclusive, exhaustive categorization), we determined the category of best fit for each study. Our methods have been updated to reflect this.
p.20 Para 1 line 6: Use of the term “improvement” makes interpreting a negative number as somewhat challenging. For example, what is a “-10” improvement? Perhaps, describe this as a “Change from baseline”? This obviously flips the y-axis but makes it much easier to interpret. This is similarly a problem in Map 6 (LWBS). | We agree, this wording has been updated as suggested
p.23 Summary and Discussion: Referencing definitions above, please verify that these measures are in fact identical. I am very skeptical that these are in fact identical. | We now describe this issue in the limitations.
Minor Comments P.1 Para 2 Line 19: Should be “LWBS” P.1 Para 2 Line 20: Should have a “.” After “excluded”. P.2 Para 1 Line 11 : The accepted term is “crowding” not “overcrowding” p.2 Para 2 line 28: There appear to be multiple uses of the term “physician triage” with references to “MD at triage”, “physician-in-triage”, and “MD Triage.” With the additional use of “team triage” the multiple terms may be confusing to the reader. I would choose one and stick with it. p.3 Para 4 line 43: Extra “,” after the period. p.9 Tables 1 and 2: I don’t understand how these tables are sorted. They do not appear to be alphabetical nor in descending in the number of projects. This order appears to be carried into the evidence maps as well. p.12 Table 3: Perhaps move to an appendix as these represent all of the studies, not just “examples.” p.18 Para 1 line 6: What is meant by “average”? Is it mean or median? | We have updated all these revisions in our text. Regarding the multiple versions of the MD triage term, we now use Physician Triage throughout. Regarding the organization of projects, we have now updated to reflect the interventions to be descending in order of number of projects. Regarding Table 3, we have shortened this table and moved the longer text into an appendix.