# APPENDIX B Study Selection Criteria

1. What is the study design?
  - Hypothesis testing
  - Other design, STOP (note if reference mining or relevant to background)
2. Should this article be excluded because:
  - 1996 publication or earlier, STOP
  - Single condition, STOP (NOTE: chest pain short stay units and studies assessing system effects are includes)
  - Related to clinical management rather than efficiency intervention, STOP
  - short stay or observation unit, no ED system outcome (eg, outcomes compared to admitted patients)
  - Include
3. What is the sample size?
  - <100
  - 100–499
  - 500–999
  - 1,000–9,999
  - >10,000
4. What is the analytic unit?
  - Patients
  - providers
  - shifts
  - facilities
5. Is the setting academically affiliated?
  - Yes
  - No
  - Both
  - Not Reported
6. Is the setting VA?
  - Yes
  - No or Not reported
7. Study setting is:
  - One site
  - Multi-site
  - Not reported
8. Country of origin:_____________
9. Which outcomes are reported?
  - Clinical outcomes (eg, health outcomes, patient satisfaction, provider satisfaction, etc)
  - LWBS/Did Not Attend/Did Not Wait
  - Time to be seen/Wait times
  - Length of stay/time spent in the ED
  - Number or Proportion of patients admitted
  - Adverse events/harms/errors
10. Does this publication discuss at least one of the following (check ALL that apply)?
  - Cost compared to inpatient admission
  - Charges to patient
  - Reimbursement
  - Accounting within hospital
  - Other cost
  - Other resource use (eg, personnel time)
  - Other efficiency or value-related data
  - Unsure
11. Does the article indicate that the intervention
  - Reallocates existing resources
  - Adds new resources/Both adds new resources and reallocates existing resources
  - Unclear
12. Input costs quantified?
  - Yes
  - No or Not reported