# APPENDIX A Search Strategy

1. Search for systematic reviews currently under development (includes furthcoming reviews & protocols) Date Searched: 7/20/16
A. Required sources: | Evidence:
AHRQ topics in development (EPC Status Report) | https://www.epc-src.org/src/logon.cfm
PROSPERO (SR registry) | http://www.crd.vork.ac.uk/PROSPERO/
DoPHER (SR Protocols) | http://eppi.ioe.ac.uk/webdatabases4/Intro.aspx?ID=9

2. Search for current systematic reviews (limited to last five years) Date Searched:
A. Required sources: | Evidence:
AHRQ: evidence reports, technology assessment s, DEcIDE proj ects | http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/; [underlined: None found]; http://www.ahrq.gov/research/findings/ta/index.html; [underlined: None found]
CADTH | https://www.cadth.ca; Patient Wait Time Monitors: Clinical Evidence; Published on: April 13, 2011; Product Line: [underlined: Rapid Response]; Project Status: Complete; Report Type: Summary of Abstracts; Result type: Report; Question; 1. What is the clinical evidence on displaying patient wait time monitors in emergency department waiting rooms?; Key Message; No relevant evidence-based studies were identified pertaining to displaying patient wait time monitors in emergency department waiting rooms.; https://www.cadth.ca/patient-wait-time-monitors-clinical-evidence
Cochrane Database of Systematic Reviews: Protocols & Reviews | http://www.ohsu.edu/xd/education/library/; Database: EBM Reviews – Cochrane Database of Systematic Reviews <2005 to July 20, 2016>; Search Strategy:; -------------------------------------------------------; 1. (emergency department or emergency room or emergency services).mp. [mp=title, short title, abstract, full text, keywords, caption text] (511); 2. (efficiency or wait* time* or length* of stay or patient satisfaction or leaving without being seen).mp. [mp=title, short title, abstract, full text, keywords, caption text] (2664); 3. 1 and 2 (234); 4. limit 3 to last 5 years (155); 5. (efficiency or wait* time* or length* of stay or patient satisfaction or leaving without being seen).ti,ab,kw. (401); 6. 1 and 5 (48); 7. limit 6 to last 5 years (31); ***************************; One systematic review identified
ECRI Institute | https://www.ecri.org/Pages/default.aspx; None found
HTA: Health Technology Assessments | http://www.ohsu.edu/xd/education/library/
MEDLINE: | http://www.ohsu.edu/xd/education/library/
Systematic Reviews | None found (primary studies below)
NHS Evidence | http://www.evidence.nhs.uk/default.aspx
NLM | http://www.ncbi.nlm.nih.gov/pubmedhealth/; None found; http://www.ncbi.nlm.nih.gov/books
VA Products -VATAP, PBM and HSR&D publications | A. http://www.hsrd.research.va.gov/research/default.cfm; None found; B. http://www.research.va.gov/research_topics/

3. Current Guidelines
National Guideline Clearinghouse | http://www.guideline.gov/
USPSTF | http://www.uspreventiveservicestaskforce.org/uspstopics.htm

B. Secondary sources^*^ | Evidence
Bluecross Blueshield Foundation Massachusetts | http://bluecrossfoundation.org/publications
Campbell Collaboration | http://www.campbellcollaboration.org/lib/?go=browse
CMS Policies | http://www.cms.gov/Research-Statistics-Data-and-Svstems/Statistics-Trends-and-Reports/Reports/Research-Reports-List.html
Hayes | http://www.havesinc.com/haves/
Institute for Clinical Evaluative Sciences | http://www.ices.on.ca/Publications/Atlases-and-Reports
IOM | http://www.iom.edu/Reports.aspx
McMaster Health Systems Evidence | http://www.healthsvstemsevidence.org/open-search.aspx
NIH Consensus Statement | http://consensus.nih.gov/previous.htm
Robert Wood Johnson | http://www.rwif.org/en/research-publications.html
Systematic Reviews (Journal): Protocols & Reviews | http://link.springer.com/journal/13643
UBC Centre for Health Services and Policy Research | http://chspr.ubc.ca/pubs/pub-search
WHO Health Evidence Network | http://www.euro.who.int/en/what-we-do/data-and-evidence/health-evidence-network-hen/publications/by-keyword

* Search secondary sources of systematic review as needed, depending on results of search of required sources and topic

C. Results of Search for SR and Protocols | Next Step
√ No relevant systematic reviews | Locate primary Literature
□ Relevant systematic review | See if it fills need
□ Relevant systematic review – out of date | Locate primary literature since SR search date
□ Many semi-relevant systematic reviews | Consider Review of Reviews or Evidence Map
□ Semi-relevant systematic review(s) | Consider revising scope if SR covers some KQ; locate primary literature with revised scope

4. Search for primary literature Date searched: 7/21/2016
[underlined: A. MEDLINE Search Strategy]; Database: Ovid MEDLINE(R) without Revisions <1996 to July Week 2 2016>, Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations <July 21, 2016>; Search Strategy:; -------------------------------------------; 1. emergency department.mp. or exp Emergency Service, Hospital/ (72136); 2. exp Efficiency/ (4763); 3. 1 and 2 (68); 4. leaving without being seen.mp. (51); 5. 1 and 4 (50); 6. limit 5 to (english language and yr=“2011-Current”) (30); 7. wait* time*.mp. (8132); 8. Patient Satisfaction/ (60618); 9. “Length of Stay”/ (52297); 10. 4 or 7 or 8 or 9 (118303); 11. 1 and 10 (5354); 12. limit 11 to (english language and yr=“2011 -Current”) (2332); 13. limit 12 to (clinical trial, all or comparative study or controlled clinical trial or “corrected and republished article” or evaluation studies or government publications or guideline or journal article or meta analysis or multicenter study or observational study or practice guideline or pragmatic clinical trial or “review” or systematic reviews or twin study or validation studies or video-audio media) (2243); 14. limit 13 to (clinical trial, all or comparative study or evaluation studies or meta analysis or multicenter study or systematic reviews) (757); 15. (children or pediatric).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier] (620022); 16. 14 not 15 (646); 17. (length of stay or leaving without being seen or patient satisfaction or wait time).ab,hw,ti. (138340); 18. leaving without being seen.ab,ti. (51); 19. “wait* time*”.ab,ti. (8109); 20. length of stay.ab,ti. (31922); 21. patient satisfaction.ab,ti. (22515); 22. 18 or 19 or 20 or 21 (61189); 23. 1 and 22 (4363); 24. limit 23 to (english language and yr=“2011 -Current”) (2266); 25. limit 24 to (clinical trial, all or comparative study or evaluation studies or journal article or meta analysis or multicenter study or randomized controlled trial or systematic reviews) (2233); 26. 25 not 15 (1903); 27. limit 26 to (clinical trial, all or comparative study or evaluation studies or meta analysis or multicenter study or randomized controlled trial or systematic reviews) (537); 537 CITATIONS IDENTIFIED; ***************************
B. Results of search for primary literature | Evidence
MEDLINE – Trials
MEDLINE – Other controlled studies
MEDLINE – Background
C. Other sources (search as needed)
CINAHL
PsycINFO
CCRCT
Google Scholar
Other specialty databases
C. Results of search for ongoing primary research | Evidence
VA ART database (Captures HSR&D funded projects) | http://art.puget-sound.med.va.gov/default.cfm
Clinicaltrials.gov

5. Final check for current systematic reviews or protocols for furthcoming systematic reviews (to see if anything has been posted since the topic work-up began and to account for shifting scope of topic) Date Searched:
Source: | Evidence:
EPC topics in development | https://www.epc-src.org/src/logon.cfm
AHRQ | http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/; http://www.ahrq.gov/research/findings/ta/index.html
CADTH | https://www.cadth.ca
Cochrane Database of Systematic Reviews | http://www.ohsu.edu/xd/education/library/
DoPHER (SR Protocols) | http://eppi.ioe.ac.uk/webdatabases4/Intro.aspx?ID=9
ECRI Institute | https://www.ecri.org/Pages/default.aspx
Health Technology Assessments | http://www.ohsu.edu/xd/education/library/
MEDLINE: Systematic Reviews | http://www.ohsu.edu/xd/education/library/
National Guideline Clearinghouse | http://www.guideline.gov/
NHS Evidence | http://www.evidence.nhs.uk/default.aspx
NLM | http://www.ncbi.nlm.nih.gov/pubmedhealth/; http://www.ncbi.nlm.nih.20v/b00ks
PROSPERO (SR registry) | http://www.crd.vork.ac.uk/PROSPERO/
USPSTF | http://www.uspreventiveservicestaskforce.or2/uspstopics.htm
VA Products – VATAP, PBM and HSR&D publications | A. http://www.hsrd.research.va.gov/research/default.cfin; B. http://www.research.va.gov/research_topics/