# RESULTS

## LITERATURE FLOW

From 13,595 titles and abstracts, 129 articles were selected for full-text review (Figure 2). Of these, we included 17, 6 providing primary data on predictive value of EWS scores and 11 pertaining to the impact of EWS interventions. We found 11 unique models ranging from 4 to 12 items with scores based on aggregate weighted systems (Table 1).

Figure 2 Literature flow diagram

Table 1 Parameters used in studies of the predictive ability and effectiveness of early warning system scores for clinical deterioration in medical and surgical inpatients

Study Country | N parameters; name of scoring system | Parameters used in the system scores
Study Country | N parameters; name of scoring system | Heart rate | Resp rate | SBP | Temp | Urine output | O2 Sat | Difficulty breathing | Supp O2 | Mental Status (LOC) | Concern | Other, specify
Rothschild, 2010^8^ USA | Single items, not combined | X | X | X | X | X | X | --- | X | X | X | DBP, seizures, uncontrolled bleeding, color change
Churpek, 2012^9^ USA | 4-item CART | X | X | --- | --- | --- | --- | --- | --- | --- | --- | DBP, Age
Maupin, 2009^10^ USA | 5-item MEWS | X | X | X | X | --- | --- | --- | --- | X | --- | ---
Jones, 2011^11^ UK | Patientrack EWS | X | X | X | X | --- | --- | --- | --- | X | --- | ---
Subbe, 2003^12^ UK | 5-item MEWS | X | X | X | X | --- | --- | --- | --- | X | --- | ---
Churpek, 2012^13^ USA | 5-item MEWS | X | X | X | X | --- | --- | --- | --- | X | --- | ---
O'Dell, 2002^14^ UK | 5-item MEWS | X | X | X | --- | X | --- | --- | --- | X | --- | ---
DeMeester, 2012^15^ Belgium | 6-item MEWS | X | X | X | X | --- | X | --- | --- | X | --- | ---
Smith, 2006^16^ UK | 6-item EWS | X | X | X | X | X | --- | --- | --- | X | --- | ---
Patel, 2011^17^ UK | 6-item MEWS | X | X | X | X | X | --- | --- | --- | X | --- | Catheterized
Kellett, 2012^18^ Canada | 6-item ViEWS | X | X | X | X | --- | X | --- | X | --- | --- | ---
Mitchell, 2010^19^ | 7-item MEWS | X | X | X | X | X | X | --- | --- | X | --- | ---
Moon, 2011^20^ UK | 7-item MEWS | X | X | X | X | X | X | --- | --- | X | --- | ---
Green, 2006^21^ Australia | 7-item clinical marker tool | X | X | X | --- | X | X | X | --- | --- | X | ---
Smith, 2013^22^ UK | 7-item NEWS | X | X | X | X | --- | X | --- | X | X | --- | ---
Prytherch, 2010^23^ UK | 7-item ViEWS | X | X | X | X | --- | X | --- | X | X | --- | ---
Albert, 2011^24^ USA | 12-item MEWS | X | X | X | X | X | X | X | X | X | X | WBC; new focal weakness

## PREDICTIVE VALUE OF EWS

Six observational studies (4 prospective cohort, 2 case-control) met our inclusion criteria (Table 2).8,9,13,18,22,23 They reported the predictive values of 4 distinct models of early warning system scores for the outcomes of interest, death and cardiac arrest within 48 hours of measurement. No study reported on the predictive ability of EWS for respiratory arrest. The studies were conducted in several countries (3 USA, 2 UK, 1 Canada) though most were in academic, urban hospitals. Although one study considered single predictors, the 4 models ranged from 4 to 7 items, all of which included heart rate, respiratory rate, and blood pressure, and most included temperature and mental status. All models were based on an aggregated weighting system. In general, the early warning system scores appeared to have strong predictive ability as judged by the area under the receiver operator characteristic curve (AUROC). Patients with favorable EWS scores were unlikely to suffer cardiac arrest or death within 48 hours. Relatively few patients had less favorable scores and while higher scores corresponded to higher rates of adverse outcomes, the sensitivity was poor as a large majority still did not.

Table 2 Observational studies of the predictive value of EWS scores

Author, Year; Model; Setting | Population; Age; Gender | Comparison | N | Predictive measures of mortality occurring within 72 hours of EWSS data collection/analysis | Predictive measures of cardiac arrest occurring within 72 hours of EWSS data collection/analysis
Churpek, 2012^9^; predictive model, retrospective cohort; US academic tertiary care hospital 500 beds | Medical/surgical pts, including telemetry pts; Mean age: Cardiac arrest pts 64 ICU Txf pts 60 Control pts 54; Male: Cardiac arrest pts 43% ICU Txf 52% Control pts 43% | Pts without an event (cardiac arrest or ICU transfer) | See previous Cardiac arrest: 88 pts ICU Txf: 2820 pts Control: 44,519 pts | NR At a specificity of 90%, the CART score (cut-off 17 of 57 possible points) sensitivity was 53%, compared to 48% for the MEWS (cut-off >4 of possible 14) for cardiac arrest. | AUROC: 0.84 (vs 0.78 for MEWS), 95% CI NR
Churpek, 2012^13^; case-control; US academic tertiary care hospital | 73% medical, 27% surgical;l Mean age: Cases 64 Controls 58 (p=0.002); Male: Cases 43% Controls 49% (P=ns) | Control pts without cardiac arrest | 88 cases, 352 controls | NR | Maximum MEWS AUC was the highest compared to other individual predictors at 0.77 (95% CI 0.71-0.82) for CA outcome. Other statistically significant AUCs were for max respiratory rate, heart rate, pulse pressure index, and minimum diastolic BP; no others were significant. Using a cut-off MEWS score of >3(of possible 14), the specificity for cardiac arrest was 87% with a sensitivity of 51%.
Kellett, 2012^18^; predictive model; Canada urban academic 375 beds | Med/Surg inpts; Mean age 63; 48.9% male | None | 75,419 total Medical, non-ICU: 43693 Surg: 30485 (presumably includes some ICU pts) | 48hr mortality AUROC for all pts: 0.93 (95% CI 0.91-0.95) AUROC for Surg: 0.89 (95% CI 0.78-1.0) AUROC for Medical, non-ICU: 0.89 (95% CI 0.85-0.92) 14% of the 519 pts with scores >11 died within 48 hours (86% false positives).
Prytherch, 2010^23^; predictive model; prospective UK Hospital | General Medical Emergency patients consecutively admitted; Mean age 67.7 Median age 72.6; 47.5% male | Pts who were alive at 24 hours following observation | 35,585 pt episodes | AUROC = 0.888 (95%CI 0.885-0.895) for death within 24 hrs Sensitivity was approximately 67% at a specificity of 90%. | NR
Rothschild, 2010^8^ case-control, predictive model; US urban academic 745 beds | Medical and medicine subspeciality inpts; Mean age: 61; 49.6% male | Control patients matched on day of admit | 262 pts 318 controls | NR | Among 26 patients with a cardiac arrest, 20 (76.9%, 95% CI 60.7-93.1%) did not have a preceding positive early warning sign.
Smith, 2013^22^ UK predictive model; prospective Hospital | General Medical patients; Mean age 67.7 Median age 72.6; 94,376/198,755 observations from males | Pts without an event | See previous | Outcome: death within 24hrs AUROC: 0.894 (95% CI 0.887-0.902) 97% of patients with a NEWS value of 8 (of 20 possible points) did not die with 24 hours. | Cardiac arrest within 24hrs AUROC: 0.857 (95% CI 0.847-0.868)

Though the included studies provide important information related to predictive ability and the studies were generally well-conducted for their study design, the body of evidence is limited by some of risk of bias (Table 3). The case-control design of 2 of the studies8,13 have the potential for bias related to differential exposure assessment as it is unclear whether vital sign measurement was different for cases compared to controls. Additionally, although 2 studies conducted validation of models,13,18 4 were derivation studies.8,9,22,23 Studies in which statistical models are derived but not validated in separate populations of patients are at risk for “over-fitting” data to the population under study. Such studies may exaggerate the predictive ability of models and, furthermore, may not be broadly applicable to populations of interest.

Table 3 Assessment of study methods for potential sources of bias in studies of the predictive value of EWS scores

Study | Study Population: study sample adequately represents population of interest | Study Attrition: study data available adequately represent study sample | Prognostic Factor Measurement: measured in a similar way for all participants | Outcomes Measurement: outcome of interest measured in similar way for all participants | Study Confounding: Important potential confounding factors are appropriately accounted for | Statistical Analysis: statistical analysis is appropriate | Reporting: All primary outcomes reported
Churpek, 2012^13^ | Yes; “consecutive” | Yes | Yes | Yes | Unclear: Cases might be significantly different from controls; not enough information provided | Yes but they conducted multiple comparisons and it doesn't look like they adjusted analyses at all (all AUCs include a 95% CI) | Yes
Kellett, 2012^18^ | Yes; “every patient” | Yes | Yes | Yes | Yes | Yes but they conducted multiple comparisons and it doesn't look like they adjusted analyses at all (all AUCs include a 95% CI) | Yes
Prytherch, 2010^23^ | Yes; “consecutive” | Yes | Yes | Yes | Yes | Yes but they conducted multiple comparisons and it doesn't look like they adjusted analyses at all (all AUCs include a 95% CI) | Yes
Rothschild, 2010^8^ | Unclear: No statement of “all” etc. | Yes | Yes | Yes | Unclear: Cases might be significantly different from controls; not enough information provided | Yes but they conducted multiple comparisons and it doesn't look like they adjusted analyses at all | Yes
Smith, 2013^22^ | Yes; “consecutive” | Yes | Yes | Yes | Yes | Yes but they conducted multiple comparisons and it doesn't look like they adjusted analyses at all (all AUCs include a 95% CI) though all p values < .001 | Yes

Kellett and colleagues provide the strongest evidence on the predictive ability of EWS scores.18 They conducted a prospective cohort study of a consecutive sample of adult patients (n=75,419) using an abbreviated version of a previously derived EWS, ViEWS (temperature, systolic blood pressure, oxygen saturation, use of supplemental oxygen, heart rate, respiratory rate). Vital signs were recorded using Vitalpac software. Among medical patients, the abbreviated ViEWS score had an area under the receiver operator characteristic curve (AUROC) of 0.89 (95% CI, 0.85-0.92) as a predictor of death within 48 hours of the observed score (from admission). This group evaluated the AUROC among multiple subsets of patients in terms of sex, year of admission, age, indication for admission (medical vs surgical), and specific diagnoses. All of the AUROC values among patients not admitted to the intensive care unit were above 0.85. Low abbreviated ViEWS scores were associated with a very good prognosis as only 11 of 49,077 total patients with scores <3 (of 21 possible points) died within 48 hours of admission. Although 14% of the 519 patients with scores >11 died within 48 hours, the false positive rate would be 86% using this cut-off.

Two other studies reported on the AUROC values utilizing the same cohort of patients. Pyrthech and colleagues conducted a prospective cohort study to derive the EWS ViEWS (plus mental status) among patients on a general medical service with vital sign data recorded using Vitalpac software (n=35,585).23 The ViEWS score had an AUROC of 0.888 (95% CI, 0.880-0.895) as a predictor of death with 24 hours of the observed score. The sensitivity of the ViEWS was approximately 67% at a specificity of 90%. They also evaluated an “efficiency curve” for the ViEWS and death within 24 hours. As an example, approximately 20% of observations had a score of 5 or more (of 21 possible points) and approximately 83% of deaths within 24 hours had a score of 5 or more. Higher scores were associated with a higher risk of death. However, using a higher cut-off lowered the sensitivity and more patients classified as low risk died.

In a related study, Smith and colleagues used the same vital sign data to evaluate the NEWS: heart rate; diastolic and systolic blood pressure; respiratory rate; oxygen saturation; temperature; and mental status using the Alert-Verbal-Painful-Unresponsive (AVPU) scale or the Glasgow Coma Score (GCS).22 The NEWS score had an AUROC of 0.894 (95% CI, 0.887-0.902) and 0.857 (95% CI, 0.847-0.868) as a predictor of death and cardiac arrest, respectively, within 24 hours of the observed score. This study did not report sensitivity at different specificities or show the ROC curve for death and cardiac arrest to estimate these data. However, as an example of the risk for a false positive, approximately 97% of patients with a NEWS value of 8 (of 20 possible points) did not die with 24 hours.

Churpek and colleagues conducted a retrospective cohort study of a novel EWS, the Cardiac Arrest Risk Triage (CART), among patients admitted to medical and surgical units, n=47,427.^9^ The CART model included respiratory rate, heart rate, diastolic blood pressure, and age. They compared the CART model to the MEWS (includes respiratory rate, pulse, systolic blood pressure, temperature, and the AVPU mental status scale) and found that the CART model was superior in predicting cardiac arrest (AUROC 0.84 vs 0.78, p = 0.001). At a specificity of 90%, the CART score (cut-off 17 of 57 possible points) had a sensitivity of 53% compared to 48% for the MEWS (cut-off >4 of possible 14) for cardiac arrest.

Churpek and colleagues found similar results in a nested case-control study (88 cases of cardiac arrest, 352 controls) of MEWS using data from the same cohort among medical and surgical patients.13 The MEWS score had an AUROC of 0.77 (95% CI, 0.71-0.82) as a predictor for cardiac arrest. Using a cut-off MEWS score of >3 (of possible 14), the specificity for cardiac arrest was 87% with a sensitivity of 51%.

Rothschild conducted an observational, case-control study (262 patients with 271 incidents of cardiac arrest and ICU transfer versus 318 controls) of at least one early warning criterion within 8 hours of a life-threatening event among medical and medicine subspecialty patients.8 Vital signs were recorded during the time the patient was on the general ward. Criteria most associated with a life-threatening event included respiratory rate >35 (OR 31.1, 95% CI, 7.5-129.6), need for supplemental oxygen to 100% or use of a non-rebreathing mask (OR 13.7, 95% CI 5.4-35), and heart rate >140/minute (OR 8, 95%CI 2.4-27.5). Multiple positive criteria were more common in cases than controls (≥3 positive criteria, 23 vs 16, p=0.00027). However, among the 26 patients with a cardiac arrest, 20 (77%) did not have a preceding positive early warning sign within 8 hours of the event.

In general, the early warning system scores appeared to have strong predictive ability for death and cardiac arrest within 48 hours however most patients with high scores did not suffer an event and low scores did not preclude one. The evidence is insufficient to determine if one system is superior to another or to determine which factors contribute most to models' predictive ability.

## IMPACT OF EWS INTERVENTIONS

We found 11 observational cohort studies with historical controls of adult patients admitted to general medical or surgical wards (n=89 to over 200,000 patients) that met our inclusion criteria for impact of EWS implementation on outcomes of 30-day mortality, cardiac arrest, and utilization of resources (Table 4).10-12,14-17,19-21,24 We found no studies reporting on the other outcomes of interest. The early warning systems ranged from 5-item to 12-item models. All included heart rate, respiratory rate, and systolic blood pressure; all but one included level of consciousness or mental status; and most included temperature and urinary output. The studies were conducted in several countries (5 UK, 2 USA, 1 Australia, 1 Belgium) and most were in academic, urban hospitals.

Table 4 Studies of the impact of EWS interventions on patient outcomes and resource utilization

Author Year; Setting | Study design | Observation period | Population N; mean age; % male; other characteristics (e.g., ward; diagnosis) | Score that triggers activation of response; Description of Response | In-hospital outcomes:; - Mortality (30-day); - Cardiovascular events | Resource utilization:; - length of hospital stay; - ICU | Resource utilization: Use of rapid response teams, Critical Care Outreach Teams or MET (medical emergency team); Nursing
Albert, 2011^24^; US 550-bed tertiary care academic hospital | Retrospective cohort; comparing MEWS score 4-8hr prior to event and at time of emergent event | 6mo pilot study | N=140; age: RRT 64.7 v code 65.8; telemetry ward | ≥3 (total 15); 1 or 2: nurse alert to reassess patient in ≤4hr; 3: discuss with charge nurse and decision made on RRT activation based on stability | NR | NR | N=78 (55.7%) RRT calls; mean MEWS for RRT 6.35; 6mo after implementation found a 33% reduction in code team calls and 50% increase in RRT calls
De Meester, 2012^15^; Belgium tertiary care hospital, 14 medical and surgical wards | Pre-retrospective and post-prospective | 5dy period after ICU discharge | N=1039; age: 59; % male: 60; MEWS at ICU discharge: 2 5-days post ICU-discharge to medical and surgical wards | Score increase by 2 points; one vital sign scored 3 points; 4: nurse felt patient unsafe (total NR); observation frequency increased to every 30min and physician notified | Patients who died without a DNR or re-admission to ICU, %: pre 5.7 vs post 3.5 ARR of 2.2% (95% CI -0.4% to -4.67%) | NR | 53% compliance for completion of MEW total population: patient observation frequency per nursing shift increased from 0.9993 (95% CI .9637-1.0035) to 1.07 (95% CI 1.10362-1.1101); p=.005; no difference during night but significant daytime increase from 1.1404(95% CI 1.1067-1.1742) to 1.2262 (95% CI 1.1899-1.2625)
Green, 2006^21^; Australia 323 bed tertiary care academic hospital surgical and medical ward | Pre-retrospective and post-prospective | Pre: February 2002-January 2003; post: February 2003-January 2005 | N=415; Demographics NR; all ward patients with abnormal VS referred to the ICU liaison team and any patient who had an unplanned admission to the ICU from the wards or who suffered a cardiac arrest/medical emergency | NR; activate ICU Liaison Team | Mortality, %: pre 33.9 vs post 34.5 | Hospital: pre 19dy vs post 16dy; ICU: pre n=153 including 111 admissions and 42 readmissions; LOS: 3.0 (1.3-6.9); post n=412 including 320 admissions and 92 readmits; LOS: median 2.6 (1.2-6.4) | Number of code blue calls, %: pre 52.1 to 35; number of code blue calls for patients still breathing and had a pulse, %: pre 47.9 to 64.4; ICU liaison Team visits: pre n=630 for 1958 visits, post n=1889 for 4586 visits; length of time on ward before admission to ICU: pre markers present for ≤6h n=90(58.8%), post n=311 (75.4%); markers present for ≥6h: pre n=63(41.2%), post 101 (24.5%), p<0.0002
Jones, 2011^11^; UK academic hospital medical assessment unit | Pre-post with 3 phases: baseline, PDA with downloading to ward-view, Patient Track; hospital and clinical outcomes and LOS collected retrospectively | Pre: 47dy November-December, 2007; alert 38dy August-September, 2008 | Baseline n=705, (7820 observations); alert phase n=776 (5848 observations); median age: 70 vs 65, p=0.01; % male: 52 vs 53; all patients admitted to ward excluding those discharged within 24hr | 3 (total 14); EWS 3-5: inform charge nurse and nurse intervention, recheck in 1hr, if still ≥3, call junior DR, if still ≥3 in 1hr, call senior DR and recheck 1hr, if still ≥call critical care medical team | Mortality, %, pre 9.5 vs post 7.6; cardiac arrest, %: pre 0.4 vs 0 | Hospital: 9.7dy vs 6.9dy, p<0.001 ICU: pre 51dy vs 26dy, p=0.04 | Clinical attendance with EWS 3-5, %: pre 29 vs post 78, p<.001; clinical attendance with EWS >5, %: pre 67 vs post 96.2; EW accuracy with electronic calculation 81%-100%; clinical attendance to patients with EWS 3, 4,or 5 increased from 29% to 78% with automated alerts, p<0.001; for EWS >5 clinical attendance increased from 67% to 95%, p<0.001; EW accuracy with electronic calculation 81%-100%; clinical attendance to patients with EWS 3,4,or 5 increased from 29% to 78% with automated alerts, p<0.001; for EWS >5 clinical attendance increased from 67% to 95%, p<0.001
Maupin, 2009^10^; US 200 bed general hospital | Pre-post; RRT calls per 1000 patient days increased from 7.8 to 16.4 after implementation (Figure 3) | Pre: 1yr (2007) pilot for 2mo post: 1yr | N=NR; general medical, surgical, tele floors | 3: increased VS frequency; 4: notify physician; 5: call RRT (total 14); EWS 3: increase VS frequency to q2 hours × 3, calculate MEWS each time. Inform charge nurse | NR, the cardiac arrest was listed as either outside ICU or not | NR | RRT calls per 1000 patient days increased from 7.8 to 16.4 after implementation
Mitchell 2010^19^; Australia 2 teaching hospitals | Before-after; | Before: 4mo; implementation: 8mo; after: 4mo | Before: n=1157, age 58.6 +/-19.7, male 55.7%; after: n=985, age 57.4 +/-19.8, male 54.8% | ≥4 | NR | ICU admissions: 1.8% vs 0.5%, RRR 0.28 (95% CI 0.11-0.74): LOS: 4.0 (1.8-8.3) vs 4.8 (2.2-9.8), p=0.03 | NR
Moon, 2011^20^; UK academic tertiary care hospital | Pre-post retrospective analysis | 8yr: pre: 2002-2005 post: 2006-2009 | Pre: 213,117 post: 235,516; demographics NR; all patients admitted to the hospital | NR (total 21); response NR | Mortality of patients undergoing in-hospital CPR, %: pre 42 vs post 52, p=0.05; hospital deaths decreased from 750/3001 to 697/2789; CV outcomes, %: pre 0.2 vs post 0.4, p<0.0001; cardiac arrests, %: 0.35 to 0.25 | Hospital: NR ICU: admissions after undergoing in-hospital CPR, %: pre 2 vs post 3, p=0.004; ICU admission after CPR, %: pre 3 vs post 2; Increase in total admissions to ICU: 857/ yr to 1135/yr | Decrease in proportion of code blue calls: pre 723/213,117 vs 668/235,516; p<0.0001
Odell, 2002^14^; UK surgical wards | Pre-retrospective vs post-prospective | 7mo pre with 3mo pilot | N=NR; surgical patients | 3 (total 15); referral to patient's medical team and the critical care outreach team | NR | NR | Calls to outreach increased from 432 in 7mo to 231 in 3mo; 70% found the outreach service “beneficial”
Patel, 2011^17^; UK trauma and orthopedic wards | Retrospective cohort - pre-post | 7yr: pre: 2002-2005; post: 2006-12/2009 | N=32149 admissions; % male: 55; trauma and orthopedic ward patients | >4 (total 21); score >4: nursing to seek senior medical advice, referral to RRT (critical care outreach team) | Proportion of percentage admissions to deaths, pre vs post: males 0.4% (95% CI 0.003-0.81) p=0.214; females 1.5% (95%CI 0.81-2.21), p=0.108; total 0.9% (95%CI 0.53-1.31%), p= 0.092 | NR | NR
Smith, 2006^16^; UK general hospital | Retrospective cohort with matched control (Legionnaire negative patients) | August 3-22, 2002 during outbreak | N= 89 Legionnaires positive, 2045 record sets vs 100 negative, 1700 record sets; median age: 64.7 vs 61.0, p<0.03; ward patients with suspected Legionnaire's disease during an outbreak | 3 (total 17); referral for critical care advice | NR | NR | Median 4.9 observation sets /patient day median 3.6 EWS/patient day; UO and LOC inconsistently recorded 2036/3739 (54.4%) observation sets contained a correct EWS; RR had highest scoring errors 264/2757 errors (9.6%) vs HR 5.4%, SBP 4.3% vs Temp 3.9%; 66/270 (24.4%) observation sets were underscored and should have triggered an intervention but did not proportion of incorrect EWS scores higher in the LP group (17%) vs LN group (12%) for difference of 5% (95% CI 0-10.7), p=0.02
Subbe, 2003^12^; UK general hospital 56-bed medical admissions unit | Pre-retrospective vs post-prospective; patients admitted to same unit in February of the previous year served as pre-intervention comparison | February-April, 2001 | Study group n=1695 vs control n=659; age: 64 vs 63; % male: 4 vs 45 | >4 (total 15); doctors examined patients within 1hr | Scores 0-2, %: 6 vs 6; score 3-4, %: 17 vs 13, p=0.29; score 5-15, %: 28 vs 20, p=0.25; ICU mortality, %: 33 vs 67, p=0.21; increased incidence of cardiopulmonary arrest in study group with score of 3 or 4, %: 5 vs 1, p<0.016 | Hospital: NR ICU: LOS in ICU was 2dy in study group vs 4dy in control, p=0.3 | NR

This represents an insufficient body of evidence due to methodological limitations. Given that all of the studies used historical controls, they are at risk of unknown, unmeasured confounding factors affecting outcomes and are subject to the effects of time. None adjusted for pre-intervention trends in mortality rate, accounted for other secular changes in care that could simultaneously have impacted mortality, and none reported or compared the rate of change for key outcomes pre-intervention (i.e., the slope of the outcome) to the rate of change (slope) of the outcome for a period of time following implementation.

## IMPACT OF EWS ON HEALTH OUTCOMES

### Mortality

We found 6 studies that directly addressed the effects of Early Warning System (EWS) implementation on mortality. Four studies found a decrease in overall mortality after implementation of an EWS,11,12,17,20 but only one study found this to be statistically significant.20 Moon et al (2011) implemented an EWS at 2 hospitals and at both institutions deaths per hospital admission decreased significantly from 1.4% to 1.2% (p<0.0001). In addition, both the mortality per cardiac arrest call and the in-hospital mortality of patients admitted to the intensive care having undergone CPR fell significantly (26% to 21%, p<0.0001 and 70% to 40%, p<0.0001, respectively). Notably, the hospitals underwent an expansion of critical care outreach services during this period so the independent impact of EWS implementation is unknown.

Mortality rates after EWS implementation were lower in 3 other studies, but none reached statistical significance.11,12,17 One additional study by DeMeester and colleagues used a combined end point of death in patients without a “Do Not Resuscitate” order or readmission to the ICU and demonstrated a non-significant decrease in this outcome.15

Conversely, in a study by Green and Williams, there was a non-significant increase in overall mortality after implementation of an EWS. However, for patients who were spontaneously breathing with a pulse at the time of “code blue” call, there was a significant improvement in survival (59% to 75%, p=0.0003).21

### Cardiac arrest

Three studies evaluating the effects of EWS implementation on cardiac arrests met inclusion criteria and found mixed results.11,12,20 No studies were found that specifically addressed pulmonary arrests, though most studies did not differentiate between cardiac and pulmonary arrests.

Moon et al found that the proportion of cardiac arrest calls per adult admission decreased in both hospitals involved in the study (0.4% to 0.2%, p<0.0001 and 0.34% to 0.28%, p<0.0001).20 Subbe et al stratified the incidence of cardiac arrest by EWS score on admission using the MEWS tool. Low (scores 0-2) and high (scores 5-15) risk groups did not have a significant difference in cardiac arrests after EWS implementation. However, the moderate risk group (scores 3-4) demonstrated a significant increase in cardiac arrests in the study population when compared to the control population (5% vs 0%, p<0.016).12 No significant difference was found in incidence of cardiac arrest after EWS implementation in the study by Jones et al.11

Two studies looked at the impact of EWS implementation on “code blue” events. In Maupin et al, the authors reported a decrease in the number of “code blues” outside the ICU from 0.77 per 1000 patient days to 0.39 per 1000 patient days, but the statistical significance was not reported.10 In the study by Green and Williams, the overall trend in cardiac arrest in relation to number of patients was not reported. However, among “code blue” calls, there was a significant decrease in the percentage of patients who had suffered cardiac arrest (52.1% to 35%, p=0.0024).21 In summary, studies on the impact of EWS scores on mortality and cardiac arrest provided limited information. In general, the data suggests a trend toward decreased mortality. However, only one study reported statistically significant improvements in overall mortality and none of the studies controlled for trends in mortality independent of the intervention. The data on cardiac arrest was even more limited and the results were mixed.

## IMPACT OF EWS ON RESOURCES

### Length of hospital stay

Three studies evaluated the impact on length of hospital stay before and after implementing an early warning system and found mixed results.11,19,21 One study included ward patients with abnormal vital signs referred to the ICU liaison team or patients with an unplanned ICU admission or medical emergency comparing data from 12 months prior to EWS implementation to 24 months after implementation.21 They found no difference in the total length of hospital stay: 19 (9-39) days vs 18 (8-33.7) days.21 The second study was similar but included all patients admitted to the ward and had a shorter pre-post design (47 days pre and 38 days post). They found a significant decrease in length of stay: 9.7 vs 6.9 days, p<0.001.^11^ The difference in study population (patients with an unplanned ICU admission or medical emergency vs all ward patients) likely accounted for the difference in outcomes. The third study compared 4 months before and 4 months after implementation and showed an increase in length of hospital stay from 4.0 (1.8-8.3) days to 4.8 (2.2-9.8) days.

### Admissions to the intensive care unit

Four studies evaluated the impact of the EWS on the number of admissions to the intensive care unit (ICU).11,12,20,21 Two studies found a significant increase in the number of ICU admissions after implementing EWS, accounting for differences in overall hospital admission rates.11,21 One study involving 2 institutions however found a decrease in the number of unplanned admissions to the ICU after implementing EWS (3% vs 2% and 6.65% vs 2.63%).20 The length of time an unstable patient was on the ward before ICU admission was found to be less after implementing EWS (percentage of patients with clinical markers of instability for ≥6 hours, 41.2% vs 24.5%)21 and 2 studies found no difference in the length of the ICU stay.12,21

### Use of rapid response and code teams

Four studies evaluated the impact of EWS on rapid response and code teams.10,20,21,24 All of the studies found at least a 50% increase in the number of rapid response or ICU liaison team calls. Three of the studies found a 6-33% decrease in the number of code blue calls.20,21,24 Of interest, one study found that the number of code blue calls for a patient still breathing and with a pulse increased from 47.9% to 64.4%.21

### Nursing

The impact on nursing was not well studied. Three studies did measure the accuracy and compliance of scoring with compliance being as low as 53% in one study15 and accuracy being as high as 81-100% with the use of electronic calculations.11 One study found that the most inconsistently recorded elements were urinary output and level of consciousness (45.6% missed values) and that respiratory rate had the highest errors (9.6%).16 The number of observations and clinical attention by nursing increased with the use of the EWS with greater attention for EWS scores >5.^11^ One study found that the frequency of patient observations per nursing shift increased during the daytime but not at night.15

In summary, the studies evaluating the impact of EWS on the use of resources are limited by their study designs and only provide a suggestion of the true effect. The results suggest that the use of staffing including nursing care and rapid response teams will increase; however, the effect on the length of hospital or ICU stay remains uncertain.