# REFERENCES

1 Whittington J, White R, Haig K, Slock M. Using an Automated Risk Assessment Report to Identify Patients at Risk for Clinical Deterioration. The Joint commission Journal on Quality and Patient Safety. 2007;33(9):569-574. [pmid: 17915531].
2 McGaughey J, Alderdice F, Fowler R, Kapila A, Mayhew A, Moutray M. Outreach and Early Warning Systems (EWS) for the prevention of intensive care admission and death of critically ill adult patients on general hospital wards. Cochrane Database Syst Rev. 2009;(3). CD005529.
3 Treadwell J, Reston J, Singh S, Talati R, McPheeters M. A. Framework for “Best Evidence” Approaches in Systematic Reviews. Methods Research Report. (Prepared by the ECRI Institute Evidence-based Practice Center under Contract No. HHSA 290-2007-10063-I.) AHRQ Publication No. 11-EHC046-EF. Rockville, MD. Agency for Healthcare Research and Quality. June. 2011. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm.
4 Iezzoni LI, editor. Risk adjustment for measuring health care outcomes. 3^rd^ ed. Chicago, IL. Health Administration Press. 2003.
5 Ohman EM, Granger CB, Harrington RA, Lee KL. Risk stratification and therapeutic decision making in acute coronary syndromes. JAMA. Aug. 16. 2000;284(7):876-878. [pmid: 10938178].
6 Schneeweiss S, Seeger JD, Maclure M, Wang PS, Avorn J, Glynn RJ. Performance of comorbidity scores to control for confounding in epidemiologic studies using claims data. American Journal of Epidemiology. Nov. 1. 2001;154(9):854-864. [pmid: 11682368].
7 Hayden JA, van der Windt DA, Cartwright JL, Cote P, Bombardier C. Assessing bias in studies of prognostic factors. Annals of Internal Medicine. Feb. 19. 2013;158(4):280-286. [pmid: 23420236].
8 Rothschild JM, Gandara E, Woolf S, Williams DH, Bates DW. Single-parameter early warning criteria to predict life-threatening adverse events. J Patient Saf. Jun. 2010;6(2):97-101. [pmid: 22130351].
9 Churpek MM, Yuen TC, Park SY, Meltzer DO, Hall JB, Edelson DP. Derivation of a cardiac arrest prediction model using ward vital signs*. Crit Care Med. Jul. 2012;40(7):2102-2108. [pmid: 22584764].
10 Maupin JM, Roth DJ, Krapes JM. Use of the Modified Early Warning Score decreases code blue events. Jt Comm J Qual Patient Saf. Dec. 2009;35(12):598-603. [pmid: 20043499].
11 Jones S, Mullally M, Ingleby S, Buist M, Bailey M, Eddleston JM. Bedside electronic capture of clinical observations and automated clinical alerts to improve compliance with an Early Warning Score protocol. Crit Care Resusc. Jun. 2011;13(2):83-88. [pmid: 21627575].
12 Subbe CP, Davies RG, Williams E, Rutherford P, Gemmell L. Effect of introducing the Modified Early Warning score on clinical outcomes, cardio-pulmonary arrests and intensive care utilisation in acute medical admissions. Anaesthesia. Aug. 2003;58(8):797-802. [pmid: 12859475].
13 Churpek MM, Yuen TC, Huber MT, Park SY, Hall JB, Edelson DP. Predicting cardiac arrest on the wards: a nested case-control study. Chest. May. 2012;141(5):1170-1176. [pmid: 22052772].
14 Odell M, Forster A, Rudman K, Bass F. The critical care outreach service and the early warning system on surgical wards. Nurs Crit Care. May-June. 2002;7(3):132-135. [pmid: 12226948].
15 De Meester K, Das T, Hellemans K, et al. Impact of a standardized nurse observation protocol including MEWS after Intensive Care Unit discharge. Resuscitation. Jul. 14. 2012.
16 Smith AF, Oakey RJ. Incidence and significance of errors in a patient ‘track and trigger’ system during an epidemic of Legionnaires' disease: retrospective casenote analysis. Anaesthesia. 2006;61(3):222-228. [pmid: 16480345].
17 Patel MS, Jones MA, Jiggins M, Williams SC. Does the use of a “track and trigger” warning system reduce mortality in trauma patients?. Injury. Dec. 2011;42(12):1455-1459. [pmid: 21696724].
18 Kellett J, Kim A. Validation of an abbreviated Vitalpac Early Warning Score (ViEWS) in 75,419 consecutive admissions to a Canadian regional hospital. Resuscitation. Mar. 2012;83(3):297-302. [pmid: 21907689].
19 Mitchell IA, McKay H, Van Leuvan C, et al. A prospective controlled trial of the effect of a multi-faceted intervention on early recognition and intervention in deteriorating hospital patients. Resuscitation. Jun. 2010;81(6):658-666. [pmid: 20378235].
20 Moon A, Cosgrove JF, Lea D, Fairs A, Cressey DM. An eight year audit before and after the introduction of modified early warning score (MEWS) charts, of patients admitted to a tertiary referral intensive care unit after CPR. Resuscitation. Feb. 2011;82(2):150-154. [pmid: 21056524].
21 Green AL, Williams A. An evaluation of an early warning clinical marker referral tool. Intensive Crit Care Nurs. Oct. 2006;22(5):274-282. [pmid: 16901699].
22 Smith GB, Prytherch DR, Meredith P, Schmidt PE, Featherstone PI. The ability of the National Early Warning Score (NEWS) to discriminate patients at risk of early cardiac arrest, unanticipated intensive care unit admission, and death. Resuscitation. Jan. 4. 2013.
23 Prytherch DR, Smith GB, Schmidt PE, Featherstone PI. ViEWS--Towards a national early warning score for detecting adult inpatient deterioration. Resuscitation. Aug. 2010;81(8):932-937. [pmid: 20637974].
24 Albert BL, Huesman L. Development of a modified early warning score using the electronic medical record. Dimens Crit Care Nurs. Sep-Oct. 2011;30(5):283-292. [pmid: 21841425].
25 Stewart JV. Vital Signs and Resuscitation. Georgetown, Texas. Landes Bioscience. 2003.
26 Rajaram SS, Desai NK, Kalra A, et al. Pulmonary artery catheters for adult patients in intensive care. Cochrane Database of Systematic Reviews. 2013:2. CD003408.
27 Wiener RS, Welch HG. Trends in the use of the pulmonary artery catheter in the United States, 1993-2004. JAMA. Jul. 25. 2007;298(4):423-429. [pmid: 17652296].
28 Ludikhuize J, de Jonge E, Goossens A. Measuring adherence among nurses one year after training in applying the Modified Early Warning Score and Situation-Background-Assessment-Recommendation instruments. Resuscitation. Nov. 2011;82(11):1428-1433. [pmid: 21719184].
29 Subbe CP, Gao H, Harrison DA. Reproducibility of physiological track-and-trigger warning systems for identifying at-risk patients on the ward. Intensive Care Med. Apr. 2007;33(4):619-624. [pmid: 17235508].
30 Prytherch DR, Smith GB, Schmidt P, et al. Calculating early warning scores--a classroom comparison of pen and paper and hand-held computer methods. Resuscitation. Aug. 2006;70(2):173-178. [pmid: 16806641].
31 Churpek MM, Yuen TC, Edelson DP. Risk stratification of hospitalized patients on the wards. Chest. Jun 1. 2013;143(6):1758-1765. [pmid: 23732586].