# METHODS

## TOPIC DEVELOPMENT

We followed a standard protocol for systematic reviews and developed an analytic framework (Figure 1) with input from key informants (clinicians, nurses, hospital administration and patient advocates) to answer the following key questions:

### Key Question 1

In adult patients admitted to the general medicine or surgical wards, what is the predictive value of EWS scores for patient health outcomes within 48 hours of data collection, including short-term mortality (all cause or disease specific), cardiac arrest and pulmonary arrest? Which factors contribute to the predictive ability of EWS scores and does predictive ability vary with specific subgroups of patients?

### Key Question 2A

What is the impact of using Early Warning Systems on patient health outcomes including 30-day mortality, cardiovascular events (cardiac arrest, acute coronary syndrome and cardiogenic shock), use of vasopressors, number of ventilator days, respiratory failure and length of hospital stay?

### Key Question 2B

What is the impact of EWS on resource utilization including but not limited to admissions to the intensive care unit (ICU), length of hospital stay, and use of Rapid Response Teams (RRT)?

We met regularly throughout the review with members of a technical expert panel, some of whom served as key informants during the development phase, to oversee the clinical applicability, content completeness, and methodological rigor of the review process.

The population comprises adults admitted to the general medicine or surgical wards. Interventions include any Early Warning System scoring or other established scoring system designed to identify deteriorating patients on hospital wards, including but not limited to Modified Early Warnings Systems (MEWS), Patient at Risk (PAR) score, Physiological Scoring Systems (PSS), Vital Sign Score (VSS), Manchester Triage System, BioSign, VitalPAC Early Warning Score (ViEWS) and Physiological Observation Track and Trigger System (POTTS).

Figure 1 Analytic Framework

## SEARCH STRATEGY

We searched MEDLINE, CINAHL, and the Cochrane Central Register of Controlled Trials for literature published from database inception to April 2013. We searched for English-language studies of EWS in medical and surgical ward populations. Appendix A provides the search strategy in detail. We obtained additional articles from systematic reviews, reference lists of pertinent studies, reviews, editorials, and by consulting experts. All citations were imported into an electronic database (EndNote X4).

## STUDY SELECTION

We included English language articles that provided primary data relevant to either key question. For studies on predictive value, we included hospital settings including the emergency department (ED). For studies on the impact of EWS intervention, we excluded studies conducted in settings other than the general medicine or surgical wards such as the emergency department (ED), and studies that did not include outcomes (opinion articles, descriptive/discussion articles, and consensus statements) or that examined outcomes outside of the proposed scope of work (e.g., impact on time interval of activating Rapid Response Team). A team of investigators individually reviewed citations and abstracts identified from electronic literature searches; if at least one reviewer indicated that a citation might be relevant, a second reviewer screened the citation for concordance. Full-text articles of potentially relevant references were retrieved for further review. Each article was independently assessed by 2 reviewers using the eligibility criteria shown in Appendix B. Disagreement was settled by consensus of the 2 investigators or by group discussion when agreement could not be reached. To assess the predictive ability of EWS, we examined observational studies reporting associations between EWS scores and 48-hour mortality, cardiac arrest, or pulmonary arrest. We chose outcomes with short time frames because the ability of models to predict longer-term clinical deterioration is not directly relevant to their utility in guiding acute care decisions.

To assess the impact of EWS on health outcomes, we included studies examining the effects of EWS interventions on 30-day mortality, cardiovascular events (cardiac arrest, acute coronary syndrome, and cardiogenic shock), use of vasopressors, number of ventilator days, and respiratory failure. We also included studies reporting the effects of EWS on the utilization of resources including admissions to the intensive care unit (ICU), use of rapid response teams (RRT), and length of hospital stay. We used a best evidence approach to guide inclusion of studies.3 After an initial search failed to identify any controlled clinical trials, we opted to include any intervention study regardless of design except for case series.

## DATA ABSTRACTION AND QUALITY ASSESSMENT

From each study, details were abstracted by one investigator and checked for accuracy by a second investigator including population characteristics, setting, number of subjects, number lost to full analysis, name and elements of scoring system, comparator, harms, implementation characteristics (e.g., staff training, pilot phase), and funding. For studies addressing the question of predictive ability, we abstracted data on model discrimination for outcomes of mortality, cardiac arrest, and pulmonary arrest within 48 hours. For all other studies we abstracted data on patient health outcomes and resource utilization.

We report the c-statistic, with 95% confidence interval when available, to describe model discrimination. The c-statistic, which is equivalent to the area under the receiver operating characteristic curve (AUROC), is the proportion of times the model correctly discriminates a pair of high- and low-risk individuals.4 A c-statistic of 0.5 indicates the model performs no better than chance; a c-statistic of 0.7 to 0.8 indicates modest or acceptable discriminative ability, and a threshold of greater than 0.8 indicates good discriminative ability.5,6 If the c-statistic was not reported, we abstracted other operational statistics such as sensitivity, specificity, and predictive values for representative risk score cut-offs when available.

For key question one, we adapted criteria described in the Quality in Prognosis Studies (QUIPS) assessment tool.7 We provide a discussion of the study strengths and limitations and describe the overall potential for bias as applicable. For key question 2, we did not find any tools designed to evaluate historically controlled study designs so provided a discussion of strengths and limitations.

## DATA SYNTHESIS

Data were synthesized qualitatively focusing on model discrimination, the populations in which the model has been tested, impact of model implementation on health outcomes and resource utilization, practical aspects of model implementation, and the types of variables included in each model. The included studies did not allow meta-analysis due to heterogeneity and qualitative nature of the data.

## ROLE OF THE FUNDING SOURCE

This research was funded by the Department of Veterans Affairs, Veterans Health Administration, Office of Research and Development, Quality Enhancement Research Initiative. The draft report was reviewed by content experts and collaborative partners. Investigators worked with VA ESP staff to develop and refine the scope, analytic framework and key questions; resolve issues arising during the project; and review the final report to ensure methodological standards for systematic reviews were met. The investigators are solely responsible for the content and the decision to submit the manuscript for publication.