# DISCUSSION

We found that early warning systems, mostly using vital sign abnormalities, seem to reasonably predict the occurrence of cardiac arrest and death within 48 hours of measurement. In general, patients with favorable EWS scores were unlikely to suffer imminent cardiac arrest or death. While patients with less favorable scores had higher rates of these adverse outcomes, a large majority did not, purporting their low sensitivity. Studies evaluating the impact of implementing EWS scores on patient outcomes and resource utilization are insufficient. The results suggest that the use of rapid response teams will increase as will the manpower to obtain, record, and react to triggering scores, but the impact on health outcomes and length of hospital or ICU stays remain uncertain.

The predictive ability of these systems for unfavorable outcomes is expected given that all of these scores are based on core signs of physiological function which have been recognized as vital to life. The term “vital sign” was first coined by Dr. Edward Seguin in 1886 and included temperature, heart rate, and respiratory rate.25 Blood pressure became a part of vital sign recording by the 20^th^ century and more recently level of consciousness has been added in response to needs of the more prevalent level one trauma hospitals.25 Although it is understood that significant alterations in these signs of life are ominous, there has remained uncertainty about the utility in recognizing early changes or some combination of early changes and whether identifying these patients improves outcomes. Our results reveal that most scoring systems have good predictive ability for cardiac arrest and mortality but studies thus far have been inconclusive as to predicting other events given the inadequacy of the evidence. We do know that their use is at the expense of increasing hospital resources.

A priori, we elected to not evaluate studies that reported predictive values for EWS on outcomes such as ICU admission because vital sign abnormality is an indication for critical care monitoring. Additionally, we only included studies that reported on critical events within 48 hours since the scores are intended to identify patients with more immediate critical needs so that interventions can be implemented before the actual event occurs. Death occurring beyond the acute time frame may actually reflect a subsequent change rather than the score that triggered the initial intervention. Kellet and colleagues, in addition to reporting death within 48 hours, also reported on death at multiple time points up to 30 days. The AUROC for all patients, including 2% admitted to an ICU, was 0.93 for death at 48 hours (14% death rate), it retained good predictive ability over time as the AUROC was 0.87 for death at 5 days and 0.81 at 30 days. Thus, it is likely that some of the strong predictive ability of an EWS to predict both short and long-term adverse outcomes is because patients with profound vital sign abnormalities are at high risk of death, regardless of specific interventions or their timeliness.

While EWS scores do have the ability to identify patients at risk of clinical deterioration, there is limited data on the impact of their implementation on patient outcomes. Despite very good diagnostic accuracy, the use of pulmonary artery catheters proved not to improve mortality among adult patients admitted to intensive care units and its use among medical patients substantially decreased.26,27 Similarly, EWS may be predictive of important outcomes but their impact on clinically important outcomes such as mortality has not been established. Although we found some evidence on the impact of implementation on mortality and cardiac arrest, we found no evidence on additional outcomes such as other cardiac events, acute coronary syndrome, use of vasopressors, number of ventilator days, respiratory failure, or quality of life at discharge. Two issues arise in studies designed to address these questions. The first is that early warning systems are frequently implemented as part of a more comprehensive critical care outreach system. In these instances, it is difficult to distinguish between the impact of the scoring system and the impact of the outreach team. We have found that the use of EWS increases the use of critical care teams and we question whether this intervention has provided the benefit rather than the EWS itself. The second issue involves controlling appropriately for the effects of time during comparative before and after study periods. Mortality or cardiac arrest numbers may decrease during the intervention phase of an EWS trial, however it is difficult to know whether this was a trend occurring naturally or in relation to concomitant and unrelated system change. Even when EWS implementation is an isolated variable in a system, there is variability in both the threshold for triggering response as well as the response that is triggered. This heterogeneity raises the possibility that it is the response to the abnormal EWS score that ultimately impacts patient outcomes rather than the use of the EWS.

Given the paucity of studies with optimal methodology, we elected to take a best evidence approach to understanding the literature by including studies providing the strongest evidence for outcomes of interest.3 However, the included studies did have significant methods and design limitations. When using studies with historical controls, there is the risk of unmeasured confounding variables and temporal bias. For example, it is very likely that vital signs are not recorded at random but are instead measured after or because of a clinical change in the patient. Thus, all these studies likely suffer from a confounding by indication bias. Furthermore, these studies likely are limited by immortal time bias since patients without adverse events have more time available for vital sign measurement.

Additionally, advances in medical care or other changes in practice cannot be ruled out as the cause of the outcomes. For example, adoption of a highly successful sepsis campaign might influence the outcome of mortality, independent of the study intervention. The strongest study design using historic controls will be: close in time compared to intervention; utilize accurate databases with little missing data; assess objective outcomes not likely to be influenced by lack of provider, participant or assessor blinding; and report a large magnitude of effect. Additionally, the best historic control group studies report both means and rate of change for key outcomes pre-intervention (i.e., the slope of the outcome) and compare this to the rate of change (slope) of the outcome for a period of time following intervention implementation. None of the included studies employed this method of slope comparison for the outcomes of interest.

Other concerns revolve around the resources needed to implement EWS. A prospective study in Amsterdam compared nurses trained to those untrained in MEWS for recognizing signs of a simulated deteriorating patient and responses to their assessments. They found that trained nurses were better able to identify and react but still missed multiple elements of the MEWS, failed to calculate the aggregate score and failed to take action informing the physician, which was part of their trained protocol.28 Other studies also reveal that accuracy and compliance of scoring is low15 particularly with respiratory rate, urinary output and more subjective elements such as level of consciousness.11,16 Calculation errors are common and although improved with an electronic system, responses to the triggering score remain variable.29-31

The applicability of our findings to real-world clinical settings is supported by several features of the body of literature we reviewed. First, the populations studied included a broad representation of patients on general medicine or surgical wards in both general hospitals and academic, tertiary care settings. The interventions or intermediate actions were similar including increase in nursing attention and activation of a critical care team or rapid response team. Other features of the studies we identified, however, limit the applicability of our findings. First, characteristics of training and implementation were varied, ranging from minimal to extensive inservice and ongoing training. Second, triggering scores to initiate increased attention or activation of a critical care outreach team were heterogeneous, as was the subsequent response. Recognizing deterioration of a patient's status often involves multiple steps, many of which occur simultaneously rather than sequentially, limiting the ability to detect the importance of each step independent of the other including the implementation of the EWS itself. Additionally, given the observational study designs, it is difficult to generalize findings as outcomes may be influenced by other features of the local environment and system changes independent of the intervention.

The most important potential limitation of our review is that due to the paucity of the evidence, we elected to follow a ‘best evidence’ approach and included studies of low methodological quality, prone to inaccuracies and leaving us with low confidence in the results. This is reflective of the early nature of this literature with the understanding that future research may substantially change our impression. It does help to inform the inadequacies of the current body of evidence in order to help shape the direction of future research. Secondly, we only searched English language studies and although we performed a comprehensive search strategy, important studies whose findings might influence clinical and policy decision making may not have been identified. Our review focused on what we identified as clinically important and temporally related outcomes of EWS systems. However, except to assess the impact on resources, we did not evaluate intermediate outcomes such as rapid response team calls and outcomes associated with their activation as this was beyond the scope of this review and it was felt that these intermediate outcomes do not necessarily reflect the important clinical outcomes. Finally, we did not evaluate or compare the different cut-offs that triggered an intervening response given that both the cut-offs and the responses were heterogeneous.

The major gaps in research identified by our review relate to the limitations of the evidence base as described above. Future studies that are randomized trials, with more rigorous adherence to methodological standards for observational studies including an active control arm with standardization of comparators and more standardized and clinically meaningful outcome measures (i.e., 48 hour cardiac or pulmonary arrest, 48 hour mortality, number of ventilator days, quality of life at discharge), are needed to inform clinical practice and policy. Standardization of cut-offs to trigger a response and standardization of responses would improve the applicability of study findings. Decisions about defining other aspects of patient populations, interventions, comparators, outcomes, study timing and duration, and study settings should be guided by clinical practice, expertise, and factors most relevant to decision makers, including patients, clinicians, and policymakers. Institutions implementing EWS systems should prospectively track use of resources while measuring these outcomes to gain better understanding of the true impact.

## CONCLUSION

Current early warning scoring systems perform well for predicting death within 48 hours although the impact on health outcomes remains uncertain given the increased use of hospital resources. Efforts to better test and improve their performance and effectiveness are needed as use becomes more widespread.