# INCLUSION/EXCLUSION CRITERIA

Code | Definition | Exclusion criteria/notes | KQ1 – Predictive value | KQ2 –Patient health outcomes and resource utilization
X1 | Non-English language
X2 | Not relevant to topic
X3 | Intervention not in scope | Exclude if the risk factors examined, methods of risk factor/exposure measurement, or early warning systems studied are not in scope. | Included interventions: any Early Warning Systems (EWS) or other established scoring system designed to identify deteriorating patients on general hospital wards. Potential interventions include but are not limited to the following: Modified Early Warnings Systems (MEWS), Patient at Risk (PAR) score, Physiological Scoring Systems (PSS), Vital Sign Score (VSS), Manchester Triage System, BioSign, VialPAC Earl Warning Score (ViEWS), and Physiological Observation Track and Trigger System (POTTS). | Same interventions as KQ1
X4 | Study population or setting not in scope | Excluded populations: obstetric, fetal, or pediatric patients; Excluded settings: emergency department, ICU, outpatient. | Admitted patients on general medicine or surgical wards. | Same populations/settings as KQ1
X5 | No primary data or study design not in scope | Excluded study designs: non-systematic or narrative reviews, opinions, case series | English language validity studies: include if the article is an observational study that reports measures of predictive ability (e.g., discriminative factor, concordance statistic, sensitivity, specificity, likelihood ratios, positive predictive value, and/or negative predictive value) and validates the predictive model. | Controlled studies: randomized controlled trials, controlled clinical trials, before and after studies, and interrupted-time-series designs. Also include: English language systematic reviews of controlled studies.
X7 | Outcomes that are not in scope | | Patient health outcomes occurring within 72 hours of EWSS data collection/analysis:; - short-term mortality (all cause or disease specific); - cardiac arrest; - pulmonary arrest | Outcomes for KQ2 generally apply to in-hospital stay:; - mortality (in-hospital or mortality up to 30-days; all cause or disease-specific); - in-hospital cardiovascular events (cardiac arrest, acute coronary syndrome, cardiogenic shock); - use of pressors; - number of ventilator (or ventilator-free) days; - respiratory failure; - length of hospital stay; - resource utilization outcomes including ICU admission and use of rapid response teams
X8 | Other reason: specify | Add comments or keywords as needed.
X99 | Full text not accessible
B | Background | Add to any of the above X codes (e.g., X6–B) if the article contains information that may be useful for the introduction, discussion, limitations, future research, or other contextual purposes. Add comments or keywords as needed.
I-1 I-2 | | | Validity studies that address: KQ1a: What is the predictive value in using EWS scores for predicting patient health outcomes? KQ1b: Which factors contribute to the predictive ability of EWS scores? KQ1c: Does predictive ability of EWS scores vary with specific subgroups of patients? | Controlled studies that address: KQ2a: What are the effects of EWS on health outcomes including mortality, morbidity, cardiac arrest, and pulmonary arrest? KQ2b: What is the impact of EWS on resource utilization (e.g., ICU admissions, length of hospital stay, use of Rapid Response Teams) and provider/nurse satisfaction?
I-SR | Include – systematic review | | Systematic review or meta-analysis that addresses either KQ1 or KQ2.