# SEARCH STRATEGIES

## PubMed searched 1/23/2013 & 1/30/2013

Search | Key Question | Concept | Search Terms
A | All | Early Warning Scoring Systems (general) EWSS – EWSS General | ((track and trigger{Title/Abstract})) OR (((((((“Hospital Information Systems”{Mesh}) OR “Risk Assessment/ methods”{Mesh}) OR “Point-of-Care Systems”{Mesh}) OR “Monitoring, Physiologic/methods”{Mesh})) OR ((clinical deterioration{Title/Abstract}) OR risk assessment report{Title/Abstract})) OR (((“early warning”{Title/ Abstract}) OR “warning system*”{Title/Abstract}) OR “warning scoring”{Title/Abstract}))
B | All | Named Systems EWSS – EWSS Named | ((((((((((bispebjerg{Title/Abstract})) OR (physiological scoring system{Title/Abstract})) OR ((vital sign{Title/Abstract}) AND score{Title/Abstract})) OR (worthing{Title/Abstract})) OR (vialpac{Title/ Abstract})) OR (sbar{Title/Abstract})) OR (situation background assessment recommendation{Title/Abstract})) OR (mews{Title/Abstract})) OR (manchester triage system{Title/Abstract})) OR (biosign{Title/Abstract})
C | All | Either of the Above | A OR B
D | KQ1 | Predictive Value EWSS -Predictive Value | ((((((((((((C statistic*{Title/Abstract})) OR (Likelihood ratio{Title/Abstract})) OR (expected to observed{Title/ Abstract})) OR (calibration{Title/Abstract})) OR (“Calibration”{Mesh})) OR (area under curve{Title/ Abstract})) OR (“Area Under Curve”{Mesh})) OR ((((PPV{Title/Abstract}) OR positive predictive value{Title/Abstract}) OR NPV{Title/Abstract}) OR negative predictive value{Title/Abstract})) OR (“Predictive Value of Tests”{Mesh})) OR (((Receiver Operating{Title/ Abstract}) OR Receiver Operator{Title/Abstract}) OR ROC{Title/Abstract})) OR (“ROC Curve”{Mesh})) OR (discriminative function{Title/Abstract})
E | KQ2 | Mortality EWSS -Mortality | ((mortality{Title/Abstract})) OR (“Hospital Mortality”{Mesh})
F | KQ2 | Length of Stay EWSS - LOS | ((“length of stay”{Title/Abstract})) OR (“Length of Stay”{Mesh})
G | KQ2 | Coronary Outcomes EWSS -Coronary | (((((cardiac arrest{Title/Abstract}) OR cardiogenic shock{Title/Abstract}) OR ACS{Title/Abstract}) OR acute coronary syndrome{Title/Abstract})) OR ((“Shock, Cardiogenic”{Mesh}) OR “Acute Coronary Syndrome”{Mesh})
H | KQ2 | Respiratory Failure EWSS - Resp | ((“Respiratory Insufficiency”{Mesh})) OR (respiratory failure{Title/Abstract})
I | KQ2 | Sepsis EWSS - Sepsis | (((“Sepsis”{Mesh}) OR “Shock, Septic”{Mesh})) OR ((sepsis{Title/Abstract}) OR septic{Title/Abstract})
J | KQ2a | ICU admissions EWSS - ICU | (((((ICU{Title/Abstract}) OR intensive care unit{Title/ Abstract})) AND ((admission{Title/Abstract}) OR admissions{Title/Abstract}))) OR ((“Patient Transfer”{Mesh}) OR “Intensive Care Units/ utilization”{Mesh})
K | KQ2a | Use of rapid response teams EWSS - RRT | ((((((medical emergency team{Title/Abstract}) OR rapid response team{Title/Abstract}) OR RRT{Title/ Abstract}) OR critical care outreach team{Title/Abstract}) OR patient at risk team{Title/Abstract})) OR ((“Patient Care Team”{Mesh}) OR “Hospital Rapid Response Team”{Mesh})
X | | Animals | Other Animals
Y | | Children | Child: birth-18 years
Z | | Labor and Fetal Monitoring EWSS - Fetal | (“Fetal Monitoring”{Mesh}) OR “Labor, Obstetric”{Mesh}

Key Question | Search
KQ 1 | Predictive Value (C AND D) Not (X,Y OR Z)
KQ2 | Mortality (C AND E) Not (X,Y OR Z)
KQ2 | Length of Stay (C AND F) Not (X,Y OR Z)
KQ2 | Coronary outcomes (C AND G) Not (X,Y OR Z)
KQ2 | Respiratory Failure (C AND H) Not (X,Y OR Z)
KQ2 | Sepsis (C AND I)
KQ2a | ICU Admissions (C AND J) Not (X,Y OR Z)
KQ2a | Rapid Response Teams (C AND K) Not (X,Y OR Z)

## CINAHL searched 3/15/13

KQ | Concept | Search Terms
All | Early Warning Scoring Systems (general) | (MH “Hospital Information Systems”) OR (MH “Risk Assessment/MT”) OR “point of care systems” OR (M H “Monitoring, Physiologic/MT”) OR “t rack and trigger” OR “clinical deterioration” OR “risk assessment report” OR “early warning” OR “warning system*” OR “warning scoring”
All | Named Systems | (TI vital sign AND TI score) OR TI bispebjerg OR TI physiological scoring system OR TI worthing OR TI vialpac OR TI sbar OR TI situation background assessment recommendation OR TI mews OR TI manchester triage system OR TI biosign
Either or the above
KQ1 | Predictive value | (M H “Calibration”) OR (MH “ROC Curve”) OR (MH “Predictive Value of Tests”) OR TI C statistic* OR TI likelihood ratio OR TI expected to observed OR TI calibration OR TI area under curve OR TI ppv OR TI positive predictive value OR TI NPV OR TI negative predictive value OR TI receiver operating OR TI receiver operator OR TI ROC OR TI discriminative function
KQ2 | Mortality | (MH “Hospital Mortality”) OR TI mortality
KQ2 | Length of Stay | (MH “Length of Stay”) OR “length of stay”
KQ2 | Coronary outcomes | (M H “Shock, Cardiogenic”) OR “cardiogenic shock” OR “ac cute coronary syndrome” OR (MH “Acute Coronary Syndrome”) OR “cardiac arrest” OR TI ACS
KQ2 | Respiratory failure | (M H “Respiratory Failure”) OR “respiratory failure”
KQ2 | Sepsis | “sepsis” OR (MH “Shock, Septic”) OR (MH “Sepsis”) OR “septic”
KQ2a | Icu admit | ((TI ICU OR TI Intensive care unit ) AND (TI Admission OR TI Admission)) OR “patient transfer” OR (M H “Intensive Care Units/UT”)
KQ2a | Use of rapid response teams | TI Medical emergency team OR “patient care team” OR “rapid response team” OR TI critical care outreach team OR TI RRT OR TI patient at risk team
All | Children | Limit: all child
All | Labor and fetal monitoring | (MH “Fetal Monitoring”) OR (MH “Labor”)

KQ | All concepts below are ANDed with the search for early warning scoring systems and have fetal monitoring, labor and children NOTed out
KQ1 | Predictive value
KQ2 | Mortality
KQ2 | Length of Stay
KQ2 | Coronary outcomes
KQ2 | Respitory failure
KQ2 | Sepsis
KQ2a | ICU admissions
KQ2a | Use of rapid response teams
All above searches de-duplicated against each other for a total of:

## Search Strategy for Cochrane Central Register of Controlled Trials (OVID) April 5, 2013

# | Searches
1 | hospital information systems.mp. or exp Hospital Information Systems/
2 | exp Risk Assessment/
3 | exp Point-of-Care Systems/
4 | exp Monitoring, Physiologic/
5 | (track and trigger).mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
6 | clinical deterioration.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
7 | risk assessment report.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
8 | early warning.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
9 | warning system*.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
10 | warning scoring.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
11 | 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10
12 | vital sign.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
13 | score.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
14 | 12 and 13
15 | bispebjerg.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
16 | physiological scoring system.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
17 | worthing.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
18 | vialpac.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
19 | sbar.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
20 | situation background assessment recommendation.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
21 | mews.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
22 | manchester triage system.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
23 | biosign.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
24 | 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23
25 | 11 or 24
26 | calibration.mp. or exp Calibration/
27 | area under curve.mp. or exp Area Under Curve/
28 | predictive value of tests.mp. or exp “Predictive Value of Tests”/
29 | roc curve.mp. or exp ROC Curve/
30 | c statistic*.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
31 | likelihood ratio.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
32 | expected to observed.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
33 | calibration.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
34 | area under curve.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
35 | ppv.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
36 | positive predictive value.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
37 | npv.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
38 | negative predictive value.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
39 | receiver operating.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
40 | reciever operator.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
41 | roc.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
42 | discriminative function.mp. {mp=title, original title, abstract, mesh headings, heading words, keyword}
43 | 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42
44 | 25 and 43

## KQ1 predictive value

# | Searches
45 | mortality.mp. or exp Hospital Mortality/
46 | length of stay.mp. or exp “Length of Stay”/
47 | cardiogenic shock.mp. or exp Shock, Cardiogenic/
48 | acute coronary syndrome.mp. or exp Acute Coronary Syndrome/
49 | cardiac arrest.mp. or exp Heart Arrest/
50 | acs.mp.
51 | 47 or 48 or 49 or 50
52 | respiratory failure.mp. or exp Respiratory Insufficiency/
53 | sepsis.mp. or exp Sepsis/
54 | exp Shock, Septic/ or septic.mp.
55 | 45 or 46 or 51 or 52 or 54
56 | 25 and 55

## KQ2 patient outcomes

Search Strategy:

# | Searches
57 | icu.mp.
58 | intensive care unit.mp.
59 | 57 or 58
60 | admission.mp.
61 | admissions.mp.
62 | 60 or 61
63 | 59 and 62
64 | exp Patient Transfer/
65 | exp Intensive Care Units/
66 | 63 or 64 or 65
67 | exp Patient Care Team/
68 | exp Hospital Rapid Response Team/
69 | medical emergency team.mp.
70 | rapid response team.mp.
71 | rrt.m titl.
72 | critical care outreach team.m_titl.
73 | patient at risk team.m_titl.
74 | 67 or 68 or 69 or 70 or 71 or 72 or 73
75 | 66 or 74
76 | 25 and 75