# RESULTS

## LITERATURE FLOW

Our search of electronic databases, bibliographies, and other sources resulted in a total of 4,364 studies. After title and abstract review, 913 met inclusion criteria. Upon full-text review, we included a total of 464 studies, with 362 studies for Key Question 1 (of which 135 reported outcomes for more than one disparity population), 64 studies for Key Question 2, and 40 for Key Question 3 (Figure 2).

Figure 2 Literature Flow Chart

* 2 studies were included for both Key Question 1 and Key Question 2.

## KEY QUESTION 1 For what Veteran groups/populations are health and healthcare disparities prevalent?

### Summary of Findings

Across all outcomes, 193 studies reported the prevalence of racial or ethnic disparities in the utilization or quality of health or healthcare in Veterans. We identified 112 studies that examined disparities affecting women, and 74 studies examined disparities affecting Veterans with mental health conditions, most commonly major depressive disorder (MDD), posttraumatic stress disorder (PTSD), and schizophrenia. Very few studies examined disparities in the health or healthcare experienced by LGBT Veterans (9 studies), and homeless Veterans (7 studies), and only a limited number of studies examined the influence of socioeconomic status (31 studies). Table 3 provides the number of identified studies by vulnerable Veteran population, for each of the 3 outcome categories (utilization, quality of care, patient health outcomes).

Table 3 Distribution of Total Studies and Studies Across Outcome Categories for Each Population

Population | Total Studies | Utilization Studies N (%) | Quality of Care Studies N (%) | Patient Health Outcome Studies N (%)
Race/Ethnicity | 193 | 24 (12.4) | 117 (60.6) | 111 (57.5)
African American/Black | 188 | 24 (12.8) | 110 (58.5) | 82 (43.6)
Hispanic/Latino | 70 | 9 (12.9) | 40 (57.1) | 26 (37.1)
American Indian/Alaska Native | 21 | 4 (19.0) | 8 (38.1) | 11 (52.4)
Asian or Asian and/or Pacific Islander^a^ | 18 | 4 (22.2) | 8 (44.4) | 9 (50.0)
Native Hawaiian and/or Pacific Islander^a^ | 5 | 1 (20.0) | 2 (40.0) | 3 (60.0)
Women | 112 | 24 (21.4) | 57 (50.9) | 41 (36.6)
Mental Health | 74 | 13 (17.6) | 44 (59.5) | 26 (35.1)
Age | 60 | 12 (20.0) | 37 (61.7) | 15 (25.0)
Rural Residence | 39 | 17 (43.6) | 15 (38.5) | 15 (38.5)
Distance | 15 | 10 (66.7) | 3 (20.0) | 4 (26.7)
Socioeconomic Status | 31 | 7 (22.6) | 15 (48.4) | 10 (32.3)
Military Era of Service | 15 | 7 (46.7) | 5 (33.3) | 6 (40.0)
Lesbian, Gay, Bisexual, Transgender | 9 | 3 (33.3) | 2 (22.2) | 9 (100)
Disability | 16 | 7 (43.8) | 7 (43.8) | 2 (12.5)
Homeless | 7 | 6 (85.7) | 1 (14.3) | 3 (42.9)

Note: Studies may be represented more than once. 135 studies examined more than one population, and studies often reported multiple outcomes that were included in more than one category; thus, the combined sum of studies across columns may exceed the total number of unique studies for a population.

a Pacific Islanders were grouped inconsistently – sometimes being combined with Asians, and other times reported separately with Native Hawaiians.

b Quality of care studies included processes of care, intermediate outcomes, and patient evaluations of care

Across all populations, 84 studies examined outcomes related to utilization, 191 studies examined the quality of care, and 153 studies examined patient health outcomes. In general, studies examining racial/ethnic disparities focused more heavily on outcomes related to the quality of care and patient health, whereas studies examining disparities related to rural residence, distance, homelessness, era of military service, and disability placed a greater emphasis on outcomes related to utilization (see Table 3 and Figure 3).

Figure 3 Evidence Map: All Studies by Outcome

Note: Studies may be represented more than once. 135 studies examined more than one population, and studies often reported multiple outcomes that were included in more than one category; thus, the combined sum of studies across columns may exceed the total number of unique studies for a population. Quality of care studies included processes of care, intermediate outcomes, and patient evaluations of care.

We grouped studies into 39 distinct but broad clinical areas. Mental health was the most widely studied, followed by cardiovascular disease, cancer, and diabetes. Most of the studies in cardiovascular disease (69.2%), cancer (76.3%), and diabetes (63.3%) reported outcomes related to the quality of care (see Appendix D for the distribution of studies by clinical area and outcome category).

### Findings According to Population

#### Race and Ethnicity

The 193 studies reporting data on the prevalence of healthcare or health disparities in Veterans by race or ethnicity largely compared the experiences of African American/Blacks to Whites (188 studies). Studies examining the prevalence of disparities affecting Hispanic/Latino Veterans (70 studies) were limited in comparison, and very few studies focused on American Indian/Alaska Natives, Asians, or Pacific Islanders (see Table 3). Across all racial and ethnic groups, patient health and quality of care-related outcomes were more frequently reported, while utilization was the focus of relatively few studies. The majority of studies found no or mixed/unclear evidence of racial or ethnic disparities, although this varied some with the outcome evaluated. The preponderance of studies examining health outcomes found no evidence of disparities. Findings amongst studies examining quality of care outcomes varied substantially with roughly equal proportions finding evidence for and against disparities, particularly for African American/Black Veterans. Mean confidence estimates for African American/Black Veterans and to a certain extent Hispanic/Latino Veterans were lower than for other racial/ethnic groups. However, this is likely a function of the larger number of studies examining these populations, and regression toward the mean. Contributing to the overall mean confidence estimates were very few prospective studies, and nearly half of the studies reported fewer than 10,000 participants. All but a very few studies controlled for confounders, and most were multi-site studies or used national administrative data. Figure 4 provides a bubble plot illustrating the number of studies providing evidence of no racial and ethnic disparities, mixed or unclear findings, or the presence of racial and ethnic disparities in Veterans for each outcome category.

Figure 4 Evidence Map: Health Disparities in Veterans by Race and Ethnicity

Legend: The bubble plot shows the number of studies identified (y-axis) that provided evidence of no disparity, mixed or unclear findings, or a disparity (x-axis) for each outcome category (utilization, quality, patient health outcomes). Quality of care studies included processes of care, intermediate outcomes, and patient evaluations of care. Bubble size represents the mean confidence score, with a range of -1 to 4.

When examining Veterans of color by racial or ethnic group, findings for both African American/Black Veterans and Hispanic/Latino Veterans were similar to the overall race/ethnicity findings. Very few studies examined utilization, and studies examining patient health reported little evidence of disparities (see Appendix E for the African American/Black evidence map and study-level data table). However, Hispanic/Latino Veterans differed from both African American/Black Veterans and the overall race/ethnicity findings when examining quality of care outcomes, with larger proportions of studies reporting evidence of a disparity or mixed/unclear findings and a smaller percentage of studies reporting evidence of no disparities (see Appendix F for the Hispanic/Latino evidence map and study-level data table). The distribution of findings for studies examining American Indian/Alaska Native Veterans was similar to the overall findings for race/ethnicity (see Appendix G for the American Indian/Alaska Native evidence map and study-level data table). Conversely, studies examining Asian, Native Hawaiian, and Pacific Islander Veterans found no clear evidence of disparities across all outcome categories. However, sample sizes were small, and there may not have been the power to detect differences (see Appendix H for the Asian/Pacific Islander evidence map and study-level data table and Appendix I for the Native Hawaiian/Pacific Islander evidence map and study-level data table).

#### Women

We identified 112 studies providing data on the presence or absence of disparities in utilization, the quality of care, and the health of female Veterans. Across all outcomes, 52 studies reported evidence of no disparity, 39 studies reported mixed or unclear findings, and 25 studies identified a disparity in health or healthcare. Half of the studies reported quality of care outcomes, with outcomes related to utilization the least represented. Across all outcomes, more studies found evidence of no disparity or mixed or unclear findings. Of the 24 studies examining disparities related to utilization only one study found evidence of a disparity – that while women Veterans did not differ from men in their use of VHA outpatient health and mental health services, their non-VHA utilization was significantly higher (see Figure 5).^33^

Figure 5 Evidence Map: Health Disparities Among Women Veterans

Legend: The bubble plot shows the number of studies identified (y-axis) that provided evidence of no disparity, mixed or unclear findings, or a disparity (x-axis) for each outcome category (utilization, quality, patient health outcomes). Quality of care studies included processes of care, intermediate outcomes, and patient evaluations of care. Bubble size represents the mean confidence score, with a range of -1 to 4.

Among studies examining gender-related disparities, we identified very few prospective studies, and the vast majority of studies were multi-site or examined national administrative data. In general, sample sizes were large, and most studies controlled for confounding variables (see Appendix J for study-level data table).

#### Mental Health

Seventy-four studies examined disparities affecting Veterans with mental health conditions. Included studies compared both Veterans with and without mental health conditions, as well as outcomes by single or comorbid mental health conditions. Across all outcomes, 15 studies found no evidence of a disparity, 32 studies reported mixed or unclear findings, and 31 studies found evidence of a disparity (see Figure 6). Studies reporting the prevalence of disparities for Veterans with mental health conditions examined outcomes related to the quality of care more than others, with a limited number of studies examining utilization. Across outcome categories, findings of a disparity or mixed or unclear findings were more common than not. There was wide variation in mean confidence estimates, due in large to the small number of studies examining disparities related to utilization or patient health outcomes (see Appendix K for the mental health study-level data table).

Figure 6 Evidence Map: Health Disparities in Veterans with a Mental Health Condition

Legend: The bubble plot shows the number of studies identified (y-axis) that provided evidence of no disparity, mixed or unclear findings, or a disparity (x-axis) for each outcome category (utilization, quality, patient health outcomes). Quality of care studies included processes of care, intermediate outcomes, and patient evaluations of care. Bubble size represents the mean confidence score, with a range of -1 to 4.

#### Other Populations

We also mapped the evidence related to the presence or absence of disparities in utilization, the quality of care, and patient health experienced by Veterans according to age (see Appendix L for the age evidence map and study-level data table), rural residence and distance from a VA Medical Center (see Appendix M for the rural residence and distance evidence map and study-level data table), socioeconomic status (see Appendix N for the socioeconomic status evidence map and study-level data table), disability (see Appendix O for the disability evidence map and study-level data table), era of military service (see Appendix P for the era of service evidence map and study-level data table), LGBT identity (see Appendix Q for the LGBT evidence map and study-level data table), and homelessness (see Appendix R for the homeless evidence map and study-level data table).

Findings varied widely by population and depended on the outcome category examined. For example, 11 of 15 of studies examining distance from a VAMC reported evidence of a disparity (8 of which examined outcomes related to utilization), as did 6 of the 7 studies examining homeless Veterans. However, only one of the 9 studies examining LGBT Veterans found evidence of a clear disparity, with 6 reporting evidence of none. Among studies examining disparities associated with socioeconomic status, few differences were reported in the quality of care. However, 6 of 10 studies examining patient health reported poorer outcomes in low SES Veterans. In studies comparing outcomes by age, a similar number of studies reported poorer outcomes associated with older or younger Veterans for both utilization and patient health outcomes. However, more studies examining the quality of care found poorer outcomes associated with older age.

### Findings by Outcome Type

#### Utilization

Across all populations, outcomes related to utilization of care were the least studied (84 studies), and utilization outcomes comprised less than a quarter of the studies examining disparities related to race/ethnicity, women, mental health conditions, age, and socioeconomic status. Conversely, a much stronger emphasis was placed on the utilization of care in studies examining disparities related to rural residence, distance from a VA medical center, era of military service, LGBT identity, disability, and homelessness. Studies examining many of the populations in which utilization outcomes were less emphasized (ie, race/ethnicity, women, mental health) reported evidence of no disparities, or findings were mixed or unclear, whereas a larger proportion of the studies in populations emphasizing utilization (ie, rural residence, distance from a VAMC, disability, homelessness) reported evidence of a disparity. Studies examining era of military service and LGBT Veterans were the exceptions, with utilization outcomes more commonly examined, but with very few disparities reported. Figure 7 highlights the number of studies reporting no disparity, mixed or unclear findings, and a disparity in utilization by population.

Figure 7 Evidence Map: Utilization by Population

#### Quality of Care

With 191 identified studies, outcomes related to the quality of care experienced by Veterans were the most widely studied, and comprised a large proportion of the outcomes of interest in populations such as race/ethnicity, mental health, women, and age. Conversely, in studies examining populations such as homeless Veterans, LGBT Veterans, and Veterans living greater distances from a VAMC, outcomes related to the quality of care were less emphasized.

For all populations but age, the distribution of studies leaned towards those reporting mixed/unclear findings or evidence of no disparities (see Figure 8).

Figure 8 Evidence Map: Quality of Care by Population

#### Health Outcomes

Of the 153 studies examining patient health outcomes, for the majority of populations, very few studies reported evidence of a disparity. The exceptions were findings related to Veterans with mental health conditions, and Veterans of lower socioeconomic status, for whom poorer health outcomes were more commonly found (see Figure 9).

Figure 9 Evidence Map: Health Outcomes by Population

## KEY QUESTION 2 What are the effects of interventions implemented within the VHA to reduce health disparities?

### Summary of Findings

We identified 64 studies of interventions implemented within the VHA which were designed to reduce health disparities. The largest number of studies were designed to mitigate disparities experienced by Veterans living in rural areas (13 studies) and those experienced by homeless or low-income Veterans (12 studies). No studies examined interventions designed to address disparities related to LGBT identity (see Table 4).

Table 4 Distribution of Total Studies and Studies Across Intervention Type for Each Population

Population | Total Studies | System-level | Technology | Provider-focused | Patient-focused | Multi-component
Rural Residence | 13 | 3 (23.1) | 7 (53.8) | 1 (7.7) | 2 (15.4) | -
Homeless/SES | 12 | 8 (66.7) | 1 (8.3) | - | 2 (16.7) | 1 (8.3)
Distance from a VA Medical Center | 11 | 4 (36.4) | 6 (54.5) | - | - | 1 (9.0)
Mental Health | 10 | 7 (70.0) | 1 (10.0) | - | 2 (20.0) | -
Race/Ethnicity | 8 | - | 1 (12.5) | 1 (12.5) | 4 (50.0) | 2 (25.0)
Women | 7 | 5 (71.4) | - | 2 (28.6) | - | -
Age | 4 | 2 (50.0) | 2 (50.0) | - | - | -
Era of Military Service | 3 | 1 (33.3) | 2 (66.7) | - | - | -
Disability | 1 | - | - | - | - | 1 (100.0)
Lesbian, Gay, Bisexual, Transgender (LGBT) | - | - | - | - | - | -
Total Key Question 2: | 64 | 30 (46.9) | 20 (31.2) | 3 (4.7) | 11 (17.2) | 5 (7.8)

Figure 10 provides a map illustrating studies by population, type of intervention studied, and study design. Colors indicate whether the study reported that the intervention was positive or equivalent (ie, non-inferiority studies), and bubble size represents the number of participants. Appendix S provides study-level detail.

Figure 10 Evidence Map: Studies Examining Interventions Designed to Reduce Health Disparities in the VHA by Population and Intervention Type

Legend: The bubble plot shows each study by population (x-axis) by intervention category (y-axis). Bubble size represents sample size, shading or no shading represents study design, and color represents intervention effectiveness.

As the bubble plot illustrates, interventions designed to mitigate health disparities in the VHA have largely been system-level and technology interventions, and with the exception of 2 studies,^34,35^ all studies reported positive or equivalent (eg, non-inferiority studies) findings, or reported findings that were mixed or unclear. Studies were largely observational in design; however, we also identified a number of smaller randomized and non-randomized controlled trials, which primarily examined technology or patient-focused interventions.

### Findings by Type of Intervention

#### System-level Interventions

The 30 studies examining system-level interventions were designed to reduce or eliminate disparities experienced by female Veterans, Veterans with mental health conditions, older adults, those living in rural areas or living a significant distance from a VA medical center, homeless Veterans, and OEF/OIF/OND Veterans. We identified no system level interventions designed to address disparities related to race or ethnicity, LGBT identity, or disability. Two-thirds of the studies focused on outcomes related to general health, with many examining utilization or the primary care experience, and 7 studies examined outcomes related to mental health. Most of the identified studies were observational, with nearly all studies retrospectively examining administrative data. We identified only 2 trials. The first compared the quality of life, psychotic symptom reduction, and substance use in homeless Veterans randomly assigned to the U.S. Department of Housing and Urban Development–Veterans Affairs Supported Housing (HUD-VASH), intensive case management (ICM), or usual care,^36^ and the second compared rates of smoking cessation in Veterans with PTSD randomly assigned to smoking cessation treatment integrated with PTSD treatment, or referral to a smoking cessation clinic.^37^ Other examples of interventions include community based outpatient clinics (CBOCs) to address distance to a VAMC, travel reimbursement, women's health clinics, co-located or integrated mental health and primary care, and primary care clinics tailored to the needs of homeless Veterans. About half of the studies reported only positive or equivalent findings, with the remainder of studies classified as mixed or unclear, most of which examined multiple outcomes. See Appendix S for more detail.

#### Technology Interventions

Twenty studies examined interventions utilizing technology – most commonly a form of telehealth. More than half of the studies were designed to mitigate disparities for rural Veterans (7 studies) or to improve access for Veterans living farther distances from a VA medical center (6 studies). Interventions also targeted older Veterans,^38,39^ American Indian/Alaska Native Veterans,^40^ homeless Veterans,^41^ OEF/OIF/OND Veterans,^42,43^ and Veterans with substance use disorders.^44^ Thirteen of the studies were trials, and 11 of the 20 studies had sample sizes smaller than 100. The largest study included 667 participants.^44^ Twelve studies examined outcomes related to mental health, with other clinical areas including cardiovascular disease,^45,46^ HIV,^47,48^ pain,^39,49,50^ neurology,^51^ and general healthcare utilization.^41^ Nearly all studies reported positive or equivalent findings. Only one study reported a negative finding. The study compared telephone-administered cognitive behavioral therapy (T-CBT) to usual care (in person CBT) at a CBOC, and found that despite treatment compliance and therapists that were assessed as highly competent, there were no time by treatment effects associated with T-CBT.^35^ See Appendix S for more detail.

#### Provider-focused Interventions

Three trials examined provider-focused interventions.^52-54^ 2 of the studies examined gender awareness/competence interventions designed to address disparities experienced by female Veterans,^53,54^ and the third focused on improving the quality of care for African American/Black Veterans.^52^ 2 studies reported positive findings,^52,55^ with one study, which compared an educational program targeting deficits in the gender awareness domains of gender-role ideology, sensitivity, and knowledge to a program on managing stress in the workplace, reporting mixed results.^53^

#### Patient-focused Interventions

The 11 studies examining patient-focused interventions targeted outcomes in a range of clinical areas, including general health,^56-58^ mental health,^34,59^ cardiovascular disease,^60,61^ diabetes,^62^ spinal cord injury,^63^ orthopedics,^64^ and osteoarthritis.^65^ All but 2 studies^64,65^ were trials. Four of the 11 studies examined interventions designed to mitigate racial or ethnic disparities,^60,62,64,65^ 2 targeted homeless Veterans,^56,59^ 2 focused on reducing disparities related to rural residence,^57,58^ 2 were designed for Veterans with mental health conditions,^34,61^ and one focused on Veterans with disabilities.^63^ We identified no studies of patient-focused interventions targeting women, age, era of military service, or LGBT identity. All but 2 studies reported positive or equivalent outcomes – one study compared a male specific and a gender neutral psychoeducational mailing about military sexual trauma to neutral topic mailing, and found no differences in utilization,^34^ and the other compared a supportive employment program for Veterans with spinal cord injuries to treatment as usual and found that the intervention had no effect on quality of life, and there was no difference between groups.^63^

#### Multicomponent Interventions

The 5 studies of multicomponent interventions were designed to reduce health disparities related to race or ethnicity,^66,67^ homelessness,^68^ rural residence,^55^ and distance from a VA medical center.^69^ Three included system level interventions,^67-69^ and 3 involved technology.^55,66,69^ Sample sizes ranged from 30^66^ to 8,866,^67^ and all studies reported positive/equivalent^55,66,69^ or mixed or unclear findings.^67,68^

## KEY QUESTION 3 What are the research projects designed to identify or mitigate health disparities currently being funded by the VA Office of Research and Development (ORD)?

### Summary of Findings

Our search for recently closed and ongoing studies (2015 to present) examining disparities in the utilization, quality of healthcare, and health of Veterans funded by the VA Office of Research and Development resulted in a total of 40 studies. Studies largely include(d) Veterans seen in VHA settings. However, a handful of abstracts did not clearly identify the setting of care, and a few others clearly examined non-VHA settings (eg, Choice, Indian Health Service). Across studies, 12 studies examine or were designed to address racial disparities, 10 studies target Veterans living in rural areas, 10 studies focus on women, 7 studies address disparities related to mental health conditions, 5 studies focus on homeless or low-income Veterans, 3 studies address disparities related to distance from a VAMC, and 1 study examines age-related disparities. We identified no studies examining the prevalence or interventions to mitigate disparities related to era of military service, LGBT identity, or disability. Figure 11 illustrates the number of studies across each Veteran population/group, and Table 5 provides more detail.

Figure 11 Number of Open and Recently Closed Health Disparity Studies Funded by the VA Office of Research and Development

Table 5 Open and Recently Closed Studies Focusing on Health Disparities, Funded by the VA Office of Research and Development

Project Number | Title | Principal Investigator | Funding End | Disparity Type
Project Number | Title | Principal Investigator | Funding End | Race | Mental Health | Gender | Rural | Age | SES | Distance
IIR 13-085 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141703943) | Improving VA Weight Management Outcomes: Role of the Residential Environment | Tarlov, E | 9/30/2017 | X | | X | X
CRE 12-012 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141701784) | Musculoskeletal Diagnoses Cohort: Examining Pain and Pain Care in the VA | Goulet, J | 5/31/2017 | X | | X
IIR 10-144 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141701664) | Racial and Ethnic Disparities in Satisfaction with VA Care | Zickmund, S | 2/28/2015 | X | | X
SDR 13-425 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141702692) | Understanding Women's Disparities in Satisfaction with VA Health Care (DISC Women) | Zickmund, S | 3/31/2016 | X | | X
CRE 12-300 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141702521) | Development and Validation of a Perceived Access Measure | Pyne, J | 2/28/2018 | X | | | | | X
CRE 12-020 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141701782) | Promoting Evidence-Based Pharmacotherapy for PTSD in CBOCs | Spoont, M | 11/30/2017 | | X | | | | | X
IIR 13-315 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141704023) | Effectiveness and Implementation of Brief Cognitive Behavioral Therapy in CBOCs | Cully, J | 4/30/2019 | | | | X | | | X
IIR 13-030 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141702897) | A Proactive Walking Trial to Reduce Pain in Black Veterans | Burgess, D | 6/30/2019 | X
PPO 13-395 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141703960) | Mental Health Disparities and Communication among African-American Veterans | Eliacin, J | 3/31/2016 | X
IIR 11-328 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141702625) | Motivating Providers to Reduce Racial Disparities in Their Own Practice | Burgess, D | 5/31/2017 | X
IIR 14-007 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141704664) | Opening the Black Box of Cultural Competence | Saha, S | 8/31/2020 | X
IIR 13-080 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141703378) | Staying Positive: An Intervention to Reduce Osteoarthritis Pain Disparities | Hausmann, L | 03/31/201 | X
PPO 14-111 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141703427) | SToRytelling to Improve DiseasE outcomes in Gout: The STRIDE-GO Study | Singh, J | 7/31/2015 | X
IIR 10-132 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141700806) | Using Stories to Address Disparities in Hypertension | Houston, T | 1/31/2016 | X
RRP 12-524 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141702533) | Access to PTSD Care among Veterans with and without Substance Use Diagnoses | Damon, A | 3/31/2015 | | X
CDP 12-255 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141702407) | Impact of Mental Illness on Veteran's Palliative Care Access and Outcomes (CDA 11-201) | Garrido, M | 9/30/2017 | X
RRP 14-180 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141703969) | Implementation of Stigma Reduction Intervention for Primary Care Providers | Mittal, D | 9/30/2015 | X
IIR 11-306 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141701681) | Improving PTSD Service Delivery for Veterans with Severe Mental Illness | Grubaugh, A | 12/31/2016 | X
IIR 13-319 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141704474) | Motivationally Enhanced Mobile Delivery of MOVE! to Veterans with Mental Illness | Cohen, A | 3/31/2017 | X
SDP 12-177 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141701880) | PACT to Improve Health Care in People with Serious Mental Illness (SMI-PACT) | Young, A | 12/31/2018 | X
CRE 12-008 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141701779) | Evaluation of Quality and Coordination of Outsourced Care for Women Veterans | Bastian, L | 2/28/2017 | | | X
CRE 12-038 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141701776) | Impacts of Delivery of Comprehensive Women's Health Care in the VA | Yano, E | 8/31/2016 | | | X
CRE 12-026 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141701775) | Implementation of VA Womens Health Patient Aligned Care Teams WH-PACTs | Yano, E | 2/28/2017 | | | X
CRE 12-039 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141701901) | Web and Shared Decision Making for Reserve/National Guard Women's PTSD Care | Sadler, A | 3/31/2017 | | | X
IIR 12-118 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141703389) | Women Veterans Cohort Study 2 | Haskell, S | 6/30/2018 | | | X
SDR 10-012 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141700489) | Women's Health Research Consortium/Practice-Based Research Network | Yano, E | 9/30/2016 | | | X
IIR 10-135 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141701423) | Behavioral Activation Therapy for Rural Veterans with Diabetes and Depression | Naik, A | 9/30/2016 | | | | X
VCA 15-245 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141704000) | Differences in Satisfaction with Choice: Laying the Foundation for the Evaluation of the Choice Act | Zickmund, S | 9/30/2015 | | | | X
IIR 15-147 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141704481) | Effectiveness of Telehealth Collaborative Care for Veterans with HIV in Rural and Outlying Settings | Ohl, M | 7/31/2018 | | | | X
CDP 12-253 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141702405) | Improving Access and Outcomes for Rural Veterans with HIV (CDA 11-211) | Ohl, M | 9/30/2017 | | | | X
CRE 12-083 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141702508) | Motivational Coaching to Enhance Mental Health Engagement in Rural Veterans | Seal, K | 7/31/2018 | | | | X
PPO 13-153 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141703221) | Personal Health Record-Facilitated Diabetes Self-Management Among Rural Veterans | Lynch, C | 6/30/2015 | | | | X
IIR 11-290 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141702538) | Tailoring Interventions for Rural Veterans: What We Need to Know | Fischer, E | 3/31/2017 | | | | X
IIR 12-063 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141702500) | VHA-Indian Health Service Collaborations in Rural Health: HBPC | Kramer, B | 12/31/2016 | | | | X
IIR 11-285 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141702011) | Computerized Cognitive Training to Improve Cognition in Diabetic Elderly Veterans | Silverman, J | 3/31/2018 | | | | | X
IIR 13-317 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141703409) | Group Motivational Interviewing (GMI) For Homeless Veterans In VA Services | Santa Ana, E | 1/31/2019 | | | | | | X
IIR 10-333 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141702451) | Improving Outcomes for Homeless Veterans with Peer Support | Ellison, M | 5/31/2017 | | | | | | X
IIR 15-095 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141704624) | Primary Care Quality and Homeless Service Tailoring | Kertesz, S | 6/30/2020 | | | | | | X
IIR 13-296 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141704031) | Systems for Helping Veterans Comprehend Electronic Health Record Notes | Yu, H | 11/30/2018 | | | | | | X
CRE 12-310 (http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141704502) | Adapting and Implementing the Blended Collaborative Care Model in CBOCs | Owen, R | 9/30/2019 | | | | | | | X