# REFERENCES

1 Department of Veterans Affairs. Blueprint for Excellence. Veterans Health Administration;2014.
2 Office of Health Equity. VHA Health Equity Action Plan. Washington, DC: Veterans Health Administration;2016.
3 Saha S, Freeman M, Toure J, Tippens K, Weeks C. Racial and Ethnic Disparities in the VA Healthcare System: A Systematic Review. Washington, DC: Department of Veterans Affairs (US);2007.
4 Quinones AR, O'Neil M, Saha S, Freeman M, Henry S, Kansagara D. Interventions to Improve Minority Health Care and Reduce Racial and Ethnic Disparities. Washington, DC: Department of Veterans Affairs, Evidence-based Synthesis Program;2011.
5 Peterson K, McCleery E, Waldrip K. Evidence Brief: Update on Prevalence of and Interventions to Reduce Racial and Ethnic Disparities within the VA. Washington, DC: Department of Veterans Affairs, Evidence-based Synthesis Program;2015.
6 National Center for Veterans Analysis and Statistics. Women Veterans Report: The Past, Present and Future of Women Veterans. Washington, DC: Department of Veterans Affairs;2017.
7 Haskell SG, Ning Y, Krebs E, . Prevalence of painful musculoskeletal conditions in female and male veterans in 7 years after return from deployment in Operation Enduring Freedom/Operation Iraqi Freedom. Clin. J. Pain. 2012;28(2):163-167.21677563
8 Whitehead AM, Czarnogorski M, Wright SM, Hayes PM, Haskell SG. Improving trends in gender disparities in the Department of Veterans Affairs: 2008–2013. Am. J. Public Health. 2014;104(S4):S529-S531.25100416
9 Goldzweig CL, Balekian TM, Rolon C, Yano EM, Shekelle PG. The state of women veterans' health research. J. Gen. Intern. Med. 2006;21(S3):S82-S92.16637952
10 Bean-Mayberry B, Batuman F, Huang C, . Systematic Review of Women Veterans Health Research 2004-2008. VA-ESP Project #05-226;2010.
11 Women Veterans Health Strategic Health Care Group. Gender Differences in Performance Measures, VHA 2008-2011. Washington, DC: Veterans Health Administration Office of Patient Care Services;2012.
12 Department of Veterans Affairs. About the Women Veterans Health Care Program. http://www.womenshealth.va.gov/WOMENSHEALTH/programoverview/about.asp.
13 Yano EM, Bastian LA, Frayne SM, . Toward a VA Women's Health Research Agenda: setting evidence-based priorities to improve the health and health care of women veterans. J. Gen. Intern. Med. 2006;21 Suppl 3(8605834):S93-101.16637953
14 Danan E, Ensrud K, Krebs E, Koeller E, MacDonald R, Velasquez T. An Evidence Map of the Women Veterans' Health Research Literature (2008 - 2015). Washington, DC: Department of Veterans Affairs, Evidence-based Synthesis Program;2016.
15 Epidemiology Program, Post-Deployment Health Group, Office of Public Health, Veterans Health Administration. Analysis of VA Health Care Utilization among Operation Enduring Freedom, Operation Iraqi Freedom, and Operation New Dawn Veterans, from 1st Qtr FY 2002 through 2nd Qtr FY 2015. Washington, DC: Department of Veterans Affairs;2015.
16 Druss BG, Reisinger Walker E. Mental Disorders and Medical Comorbidity. Rober Wood Johnson Foundation;2011.
17 Gierisch J, Beadles C, Shapiro A, . Health Disparities in Quality indicators of Healthcare Among Adults with Mental Illness. Washington, DC: Department of Veterans Affairs, Evidence-based Synthesis Program;2014.
18 VHA Office of Rural Health. Fact Sheet: Information about the VHA Office of Rural Health and Rural Veterans. 2014.
19 Weeks WB, Wallace AE, West AN, Heady HR, Hawthorne K. Research on rural veterans: an analysis of the literature. J. Rural Health. 2008;24(4):337-344.19007387
20 Spoont M, Greer N, Su J, Fitzgerald P, Rutks I, Wilt TJ. Rural vs. Urban Ambulatory Health Care: A Systematic Review. VA-ESP Project #09-009;2011.
21 Kehle SM, Greer N, Rutks I, Wilt TJ. Interventions to Improve Veterans' Access to Care: A Systematic Review of the Literature. Washington, DC: Department of Veterans Affairs, Evidence-based Synthesis Program;2011.
22 Gates GJ. Lesbian, Gay, and Bisexual Men and Women in the US Military: Updated Estimates. Los Angeles, CA: The Williams Institute;2010.
23 Gates GJ. Gay Men and Lesbians in the U.S. Military: Estimates from Census 2000. Washington, DC: Urban Institute;2004.
24 Gates GJ, Herman JL. Transgender Military Service in the United States. Los Angeles, CA: The Williams Institute;2010.
25 Brown GR, Jones KT. Mental Health and Medical Health Disparities in 5135 Transgender Veterans Receiving Healthcare in the Veterans Health Administration: A Case–Control Study. LGBT health. 2015.
26 Blosnich JR, Silenzio VM. Physical health indicators among lesbian, gay, and bisexual US veterans. Ann. Epidemiol. 2013;23(7):448-451.23688720
27 Mattocks KM, Sullivan JC, Bertrand C, Kinney RL, Sherman MD, Gustason C. Perceived Stigma, Discrimination, and Disclosure of Sexual Orientation Among a Sample of Lesbian Veterans Receiving Care in the Department of Veterans Affairs. LGBT health. 2015;2(2):147-153.26790121
28 Department of Veterans Affairs. Patient Care Services: Lesbian, Gay, Bisexual and Transgender (LGBT) Veteran Care.
29 Sherman MD, Kauth MR, Shipherd JC, Street RL. Provider beliefs and practices about assessing sexual orientation in two veterans health affairs hospitals. LGBT Health. 2014;1(3):185-191.26789711
30 Saha S, Freeman M, Toure J, Tippens KM, Weeks C. Racial and Ethnic Disparities in the VA Healthcare System: A Systematic Review. Washington, DC: Department of Veterans Affairs, Evidence-based Synthesis Program;2007.
31 Relevo R, Paynter R. Peer review of search strategies. 2012.
32 Sampson M, McGowan J, Cogo E, Grimshaw J, Moher D, Lefebvre C. An evidence-based practice guideline for the peer review of electronic search strategies. J. Clin. Epidemiol. 2009;62(9):944-952.19230612
33 Elhai JD, Grubaugh AL, Richardson JD, Egede LE, Creamer M. Outpatient medical and mental healthcare utilization models among military veterans: results from the 2001 National Survey of Veterans. J. Psychiatr. Res. 2008;42(10):858-867.18005993
34 Turchik JA, Rafie S, Rosen CS, Kimerling R. Preferences for gender-targeted health information: a study of male veterans who have experienced military sexual trauma. American journal of men's health. 2014;8(3):240-248.
35 Mohr DC, Carmody T, Erickson L, Jin L, Leader J. Telephone-administered cognitive behavioral therapy for veterans served by community-based outpatient clinics. J. Consult. Clin. Psychol. 2011;79(2):261-265.21299274
36 O'Connell MJ, Kasprow WJ, Rosenheck RA. Differential impact of supported housing on selected subgroups of homeless veterans with substance abuse histories. Psychiatr. Serv. 2012;63(12):1195-1205.23117205
37 McFall M, Saxon AJ, Malte CA, . Integrating tobacco cessation into mental health care for posttraumatic stress disorder: a randomized controlled trial. JAMA. 2010;304(22):2485-2493.21139110
38 Egede LE, Acierno R, Knapp RG, . Psychotherapy for depression in older veterans via telemedicine: A randomised, open-label, non-inferiority trial. Lancet Psychiatry. 2015;2(8):693-701.26249300
39 Carmody TP, Duncan CL, Huggins J, . Telephone-delivered cognitive-behavioral therapy for pain management among older military veterans: a randomized trial. Psychol. Serv. 2013;10(3):265-275.23244028
40 Shore JH, Brooks E, Savin D, Orton H, Grigsby J, Manson SM. Acceptability of telepsychiatry in American Indians. Telemed J. E Health. 2008;14(5):461-466.18578681
41 McInnes DK, Petrakis BA, Gifford AL, . Retaining homeless veterans in outpatient care: a pilot study of mobile phone text message appointment reminders. Am. J. Public Health. 2014;104 Suppl 4(1254074, 3xw):S588-594.25100425
42 Stecker T, McHugo G, Xie H, Whyman K, Jones M. RCT of a brief phone-based CBT intervention to improve PTSD treatment utilization by returning service members. Psychiatric services (Washington, D.C.). 2014;65(10):1232-1237.
43 Brief DJ, Rubin A, Keane TM, . Web intervention for OEF/OIF veterans with problem drinking and PTSD symptoms: a randomized clinical trial. J. Consult. Clin. Psychol. 2013;81(5):890-900.23875821
44 McKellar J, Wagner T, Harris A, Oehlert M, Buckley S, Moos R. One-year outcomes of telephone case monitoring for patients with substance use disorder. Addict. Behav. 2012;37(10):1069-1074.22651986
45 Singh LG, Accursi M, Korch Black K. Implementation and outcomes of a pharmacist-managed clinical video telehealth anticoagulation clinic. Am. J. Health Syst. Pharm. 2015;72(1):70-73.25511842
46 Wakefield B, Drwal K, Scherubel M, Klobucar T, Johnson S, Kaboli P. Feasibility and effectiveness of remote, telephone-based delivery of cardiac rehabilitation. Telemed J. E Health. 2014;20(1):32-38.24161003
47 Ohl M, Dillon D, Moeckli J, . Mixed-methods evaluation of a telehealth collaborative care program for persons with HIV infection in a rural setting. J. Gen. Intern. Med. 2013;28(9):1165-1173.23475640
48 Knapp H, Chan K, Anaya HD, Goetz MB. Interactive internet-based clinical education: an efficient and cost-savings approach to point-of-care test training. Telemed J. E Health. 2011;17(5):335-340.21492031
49 Tan G, Teo I, Srivastava D, . Improving access to care for women veterans suffering from chronic pain and depression associated with trauma. Pain medicine (Malden, Mass.). 2013;14(7):1010-1020.
50 Desko L, Nazario M. Evaluation of a clinical video telehealth pain management clinic. J. Pain Palliat Care Pharmacother. 2014;28(4):359-366.25383664
51 Davis LE, Coleman J, Harnar J, King MK. Teleneurology: successful delivery of chronic neurologic care to 354 patients living remotely in a rural state. Telemed J. E Health. 2014;20(5):473-477.24617919
52 Petersen LA, Ramos KS, Pietz K, Woodard LD. Impact of a pay-for-performance program on care for black patients with hypertension: important answers in the era of the Affordable Care Act. Health Serv Res. Jun 22 2016.
53 Vogt DS, Barry AA, King LA. Toward gender-aware health care: evaluation of an intervention to enhance care for female patients in the VA setting. J. Health Psychol. 2008;13(5):624-638.18519436
54 Fox AB, Hamilton AB, Frayne SM, . Effectiveness of an evidence-based quality improvement approach to cultural competence training: the Veterans Affairs' “Caring for Women Veterans” program. J. Contin. Educ. Health Prof. 2016;36(2):96-103.27262152
55 McFarland LV, Raugi GJ, Taylor LL, Reiber GE. Implementation of an education and skills programme in a teledermatology project for rural veterans. J. Telemed. Telecare. 2012;18(2):66-71.22198956
56 O'Toole TP, Johnson EE, Borgia ML, Rose J. Tailoring outreach efforts to increase primary care use among homeless veterans: results of a randomized controlled trial. J. Gen. Intern. Med. 2015;30(7):886-898.25673574
57 Mahaney-Price AF. Enabling advance directive completion by rural Alabama veterans: a pilot study. HSR&D study (NRI 10-311). 2014; http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141702007. Accessed November 14, 2016.
58 Hilgeman MM, Mahaney-Price AF, Stanton MP, . Alabama Veterans Rural Health Initiative: a pilot study of enhanced community outreach in rural areas. J. Rural Health. 2014;30(2):153-163.24330220
59 Winn JL, Shealy SE, Kropp GJ, Felkins-Dohm D, Gonzales-Nolas C, Francis E. Housing assistance and case management: improving access to substance use disorder treatment for homeless veterans. Psychol. Serv. 2013;10(2):233-240.23356857
60 Houston T. Using stories to address disparities in hypertension. HSR&D study (IIR 10-132). 2016; http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141700806. Accessed November 14, 2016.
61 Kilbourne AM, Goodrich DE, Lai Z, . Randomized controlled trial to assess reduction of cardiovascular disease risk in patients with bipolar disorder: the Self-Management Addressing Heart Risk Trial (SMAHRT). J. Clin. Psychiatry. 2013;74(7):e655-662.23945460
62 Long JA, Jahnle EC, Richardson DM, Loewenstein G, Volpp KG. Peer mentoring and financial incentives to improve glucose control in African American veterans: a randomized trial. Ann. Intern. Med. 2012;156(6):416-424.22431674
63 Ottomanelli L, Barnett SD, Goetz LL. A prospective examination of the impact of a supported employment program and employment on health-related quality of life, handicap, and disability among Veterans with SCI. Qual. Life Res. 2013;22(8):2133-2141.23345022
64 Ibrahim SA, Hanusa BH, Hannon MJ, Kresevic D, Long J, Kent Kwoh C. Willingness and access to joint replacement among African American patients with knee osteoarthritis: a randomized, controlled intervention. Arthritis Rheum. 2013;65(5):1253-1261.23613362
65 Weng HH, Kaplan RM, Boscardin WJ, . Development of a decision aid to address racial disparities in utilization of knee replacement surgery. Arthritis Rheum. 2007;57(4):568-575.17471558
66 Allen K. Tailoring coping skills training for African Americans with osteoarthritis. HSR&D study (PPO 09-240). 2011; http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141700205. Accessed November 14, 2016.
67 Kressin NR, Long JA, Glickman ME, . A brief, multifaceted, generic intervention to improve blood pressure control and reduce disparities had little effect. Ethn. Dis. Jan 21 2016;26(1):27-36.26843793
68 Smelson DA, Kline A, Kuhn J, . A wraparound treatment engagement intervention for homeless veterans with co-occurring disorders. Psychol. Serv. 2013;10(2):161-167.23244030
69 Fortney JC, Pyne JM, Edlund MJ, . A randomized trial of telemedicine-based collaborative care for depression. J. Gen. Intern. Med. 2007;22(8):1086-1093.17492326
70 Agarwal R, Bunaye Z, Bekele DM, Light RP. Competing risk factor analysis of end-stage renal disease and mortality in chronic kidney disease. Am. J. Nephrol. 2008;28(4):569-575.18239383
71 Allott EH, Howard LE, Song H-J, . Racial differences in adipose tissue distribution and risk of aggressive prostate cancer among men undergoing radiotherapy. Cancer Epidemiol. Biomarkers Prev. 2014;23(11):2404-2412.25146088
72 Alston R, Lewis A, Loggins S. Assistive technology and veterans with severe disabilities: examining the relationships among race, personal factors, medical support, income support, and use. Med. Care. 2014;52(10 Suppl 3):S17-24.
73 Arora P, Rajagopalan S, Patel N, Nainani N, Venuto RC, Lohr JW. The MDRD equation underestimates the prevalence of CKD among blacks and overestimates the prevalence of CKD among whites compared to the CKD-EPI equation: a retrospective cohort study. BMC Nephrol. 2012;13(100967793):4.22264268
74 Aujesky D, Long JA, Fine MJ, Ibrahim SA. African American race was associated with an increased risk of complications following venous thromboembolism. J. Clin. Epidemiol. 2007;60(4):410-416.17346616
75 Axon RN, Gebregziabher M, Echols C, Msph GG, Egede LE. Racial and ethnic differences in longitudinal blood pressure control in veterans with type 2 diabetes mellitus. J. Gen. Intern. Med. 2011;26(11):1278-1283.21671132
76 Ayotte BJ, Kressin NR. Race differences in cardiac catheterization: the role of social contextual variables. J. Gen. Intern. Med. 2010;25(8):814-818.20383600
77 Backus LI, Belperio PS, Loomis TP, Mole LA. Impact of Race/Ethnicity and Gender on HCV Screening and Prevalence Among US Veterans in Department of Veterans Affairs Care. Am. J. Public Health. Sep 2014;104(Suppl 4):S555-561.25100421
78 Banerjea R, Sambamoorthi U, Smelson D, Pogach LM. Chronic illness with complexities: Mental illness and substance use among veteran clinic users with diabetes. Am. J. Drug Alcohol Abuse. 2007;33(6):807-821.17994477
79 Banerjea R, Pogach LM, Smelson D, Sambamoorthi U. Mental illness and substance use disorders among women veterans with diabetes. Womens Health Issues. 2009;19(6):446-456.19879456
80 Banez LL, Terris MK, Aronson WJ, . Race and time from diagnosis to radical prostatectomy: does equal access mean equal timely access to the operating room?-- Results from the SEARCH database. Cancer Epidemiol. Biomarkers Prev. 2009;18(4):1208-1212.19336564
81 Bean-Mayberry B, Yano EM, Mor MK, Bayliss NK, Xu XY, Fine MJ. Does sex influence immunization status for influenza and pneumonia in older veterans. J. Am. Geriatr. Soc. 2009;57(8):1427-1432.19515114
82 Bierman AS, Pugh MJ, Dhalla I, . Sex differences in inappropriate prescribing among elderly veterans. Am. J. Geriatr. Pharmacother. Jun 2007;5(2):147-161.17719517
83 Boehmer U, Glickman M, Jones JA, . Dental care in an equal access system valuing equity: are there racial disparities? Med. Care. Nov 2016;54(11):998-1004.27219638
84 Borrero S, Mor MK, Zhao X, McNeil M, Ibrahim S, Hayes P. Contraceptive care in the VA health care system. Contraception. 2012;85(6):580-588.22176794
85 Borrero S, Zhao X, Mor MK, Schwarz EB, Good CB, Gellad WF. Adherence to hormonal contraception among women veterans: differences by race/ethnicity and contraceptive supply. Am. J. Obstet. Gynecol. Aug 2013;209(2):103.e101-111.23524170
86 Braun UK, McCullough LB, Beyth RJ, Wray NP, Kunik ME, Morgan RO. Racial and ethnic differences in the treatment of seriously ill patients: a comparison of African-American, Caucasian and Hispanic veterans. J. Natl. Med. Assoc. 2008;100(9):1041-1051.18807433
87 Bravata D. Racial Disparities in Blood Pressure Management Among Stroke Patients. HSR&D study (RRP 07-293). 2008; http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141697820. Accessed November 14, 2016.
88 Buchanan PM, Kramer JR, El-Serag HB, . The quality of care provided to patients with varices in the department of Veterans Affairs. Am. J. Gastroenterol. 2014;109(7):934-940.24989087
89 Burgess DJ, van Ryn M, Grill J, . Presence and correlates of racial disparities in adherence to colorectal cancer screening guidelines. J. Gen. Intern. Med. 2011;26(3):251-258.21088920
90 Burgess DJ. Presence and Correlates of Racial Disparities in Pain Management. HSR&D study (IAA 07-071). 2011; http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141699803. Accessed November 14, 2016.
91 Burgess DJ, Gravely AA, Nelson DB, . A national study of racial differences in pain screening rates in the VA health care system. Clin. J. Pain. 2013;29(2):118-123.23183265
92 Burgess DJ, Nelson DB, Gravely AA, . Racial differences in prescription of opioid analgesics for chronic noncancer pain in a national sample of veterans. J. Pain. 2014;15(4):447-455.24440840
93 Butt AA, Justice AC, Skanderson M, Good C, Kwoh CK. Rates and predictors of hepatitis C virus treatment in HCV-HIV-coinfected subjects. Aliment. Pharmacol. Ther. 2006;24(4):585-591.16907891
94 Cannon KT, Sarrazin MV, Rosenthal GE, Curtis AE, Thomas KW, Kaldjian LC. Use of mechanical and noninvasive ventilation in black and white chronic obstructive pulmonary disease patients within the Veterans Administration health care system. Med. Care. 2009;47(1):129-133.19106742
95 C'De Baca J, Castillo DT, Mackaronis JE, Qualls C. Ethnic Differences in Personality Disorder Patterns among Women Veterans Diagnosed with PTSD. Behavioral sciences (Basel, Switzerland). 2014;4(1):72-86.
96 Cecere LM, Slatore CG, Uman JE, . Adherence to long-acting inhaled therapies among patients with chronic obstructive pulmonary disease (COPD). COPD. 2012;9(3):251.22497533
97 Chapko M. Hepatitis C Antiviral Treatment Rates: Understanding Racial Disparities. HSR&D study (IAA 06-213). 2013; http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141699761. Accessed November 14, 2016.
98 Cheng EM, Keyhani S, Ofner S, . Lower use of carotid artery imaging at minority-serving hospitals. Neurology. 2012;79(2):138-144.22700815
99 Choi A, Rodriguez R, Bacchetti P, Bertenthal D, Volberding P, O'Hare A. Racial differences in end-stage renal disease rates in HIV infection versus diabetes. J. Am. Soc. Nephrol. 2007;18(11):2968-2974.17942954
100 Choi AI, Rodriguez RA, Bacchetti P, Bertenthal D, Hernandez GT, O'Hare AM. White/black racial differences in risk of end-stage renal disease and death. Am. J. Med. 2009;122(7):672-678.19559170
101 Cone C, Murata G, Myers O. Demographic determinants of response to statin medications. Am. J. Health Syst. Pharm. Mar 15 2011;68(6):511-517.21378299
102 Copeland LA, Zeber JE, Salloum IM, Pincus HA, Fine MJ, Kilbourne AM. Treatment adherence and illness insight in veterans with bipolar disorder. J. Nerv. Ment. Dis. Jan 2008;196(1):16-21.18195637
103 Copeland LA, Zeber JE, Pugh MJ, Phillips KL, Lawrence VA. Ethnicity and Race Variations in Receipt of Surgery among Veterans with and without Depression. Depression research and treatment. 2011;2011(101546752):370962.22013518
104 Copeland LA, McIntyre RT, Stock EM, Zeber JE, MacCarthy DJ, Pugh MJ. Prevalence of suicidality among Hispanic and African American veterans following surgery. Am. J. Public Health. 2014;104 Suppl 4(1254074, 3xw):S603-608.25100427
105 Curran GM, Stecker T, Han X, Booth BM. Individual and program predictors of attrition from VA substance use treatment. J. Behav. Health Serv. Res. 2009;36(1):25-34.18188705
106 Dahodwala N, Karlawish J, Siderowf A, Duda JE, Mandell DS. Delayed Parkinson's disease diagnosis among African-Americans: the role of reporting of disability. Neuroepidemiology. 2011;36(3):150-154.21508648
107 Daskivich T, Kwan L, Dash A, Litwin M. Racial parity in tumor burden, treatment choice and survival outcomes in men with prostate cancer in the VA healthcare system. Prostate Cancer Prostatic Dis. 2015;18(2):104-109.25582624
108 Deswal A, Petersen NJ, Urbauer DL, Wright SM, Beyth R. Racial variations in quality of care and outcomes in an ambulatory heart failure cohort. Am. Heart J. 2006;152(2):348-354.16875921
109 Dismuke CE, Gebregziabher M, Egede LE. Racial/ethnic disparities in VA services utilization as a partial pathway to mortality differentials among veterans diagnosed with TBI. Global journal of health science. 2016;8(2):260.
110 Dobscha SK, Soleck GD, Dickinson KC, . Associations between race and ethnicity and treatment for chronic pain in the VA. J. Pain. 2009;10(10):1078-1087.19800567
111 Duffy SA, Kilbourne AM, Austin KL, . Risk of smoking and receipt of cessation services among veterans with mental disorders. Psychiatr. Serv. Apr 2012;63(4):325-332.22337005
112 Egede LE, Mueller M, Echols CL, Gebregziabher M. Longitudinal differences in glycemic control by race/ethnicity among veterans with type 2 diabetes. Med. Care. Jun 2010;48(6):527-533.20473215
113 Egede LE, Gebregziabher M, Lynch CP, Gilbert GE, Echols C. Longitudinal ethnic differences in multiple cardiovascular risk factor control in a cohort of US adults with diabetes. Diabetes Res. Clin. Pract. 2011;94(3):385-394.21903291
114 Egede LE, Gebregziabher M, Hunt KJ, . Regional, geographic, and ethnic differences in medication adherence among adults with type 2 diabetes. Ann. Pharmacother. 2011;45(2):169-178.21304026
115 Egede LE, Gebregziabher M, Hunt KJ, . Regional, geographic, and racial/ethnic variation in glycemic control in a national sample of veterans with diabetes. Diabetes Care. 2011;34(4):938-943.21335370
116 Egede LE, Dismuke C, Echols C. Racial/Ethnic disparities in mortality risk among US veterans with traumatic brain injury. Am. J. Public Health. 2012;102 Suppl 2(1254074, 3xw):S266-271.21852658
117 Egede LE, Lynch CP, Gebregziabher M, . Differential impact of longitudinal medication non-adherence on mortality by race/ethnicity among veterans with diabetes. J. Gen. Intern. Med. Feb 2013;28(2):208-215.22948932
118 Ellis C, Zhao Y, Egede LE. Racial/ethnic differences in stroke mortality in veterans. Ethn. Dis. 2009;19(2):161-165.19537227
119 Ellis C, Zhao Y, Egede LE. Racial/ethnic disparities in poststroke outpatient rehabilitation among veterans. J. Natl. Med. Assoc. 2010;102(9):817-822.20922926
120 Ellis C, Knapp RG, Gilbert GE, Egede LE. Factors associated with delays in seeking treatment for stroke care in veterans. J. Stroke Cerebrovasc. Dis. 2013;22(7):e136-141.23219014
121 El-Serag HB,Kramer J, Duan Z, Kanwal F. Racial differences in the progression to cirrhosis and hepatocellular carcinoma in HCV-infected veterans. Am. J. Gastroenterol. 2014;109(9):1427-1435.25070058
122 Fischer SM, Kutner JS, Sauaia A, Kramer A. Lack of ethnic differences in end-of-life care in the Veterans Health Administration. Am. J. Hosp. Palliat. Care. 2007;24(4):277-283.17582027
123 Fischer EP, McCarthy JF, Ignacio RV, . Longitudinal patterns of health system retention among veterans with schizophrenia or bipolar disorder. Community Ment. Health J. 2008;44(5):321-330.18401711
124 Fisher DA, Jeffreys A, Coffman CJ, Fasanella K. Barriers to full colon evaluation for a positive fecal occult blood test. Cancer Epidemiol. Biomarkers Prev. 2006;15(6):1232-1235.16775188
125 Frei CR, Mortensen EM, Copeland LA, . Disparities of care for African-Americans and Caucasians with community-acquired pneumonia: a retrospective cohort study. BMC Health Serv. Res. 2010;10(101088677):143.20507628
126 Gaines AR, Turner EL, Moorman PG, . The association between race and prostate cancer risk on initial biopsy in an equal access, multiethnic cohort. Cancer Causes Control. 2014;25(8):1029-1035.24879044
127 Ganti AK, Subbiah SP, Kessinger A, Gonsalves WI, Silberstein PT, Loberiza FR, Jr.Association between race and survival of patients with non--small-cell lung cancer in the United States veterans affairs population. Clin. Lung Cancer. 2014;15(2):152-158.24361249
128 Garrido MM, Prigerson HG, Penrod JD, Jones SC, Boockvar KS. Benzodiazepine and sedative-hypnotic use among older seriously Ill veterans: choosing wisely? Clin. Ther. 2014;36(11):1547-1554.25453732
129 Gebregziabher M, Lynch CP, Mueller M, . Using quantile regression to investigate racial disparities in medication non-adherence. BMC Med. Res. Methodol. 2011;11:88.21645379
130 Gerber MR, King MW, Pineles SL, . Hormone therapy use in women veterans accessing veterans health administration care: a national cross-sectional study. J. Gen. Intern. Med. 2015;30(2):169-175.25373833
131 Giordano TP, Morgan RO, Kramer JR, . Is there a race-based disparity in the survival of veterans with HIV? J. Gen. Intern. Med. 2006;21(6):613-617.16808745
132 Goldstein KM, Melnyk SD, Zullig LL, . Heart matters: Gender and racial differences cardiovascular disease risk factor control among veterans. Womens Health Issues. 2014;24(5):477-483.25213741
133 Gordon HS, Street RL, Jr., Sharf BF, Souchek J. Racial differences in doctors' information-giving and patients' participation. Cancer. 2006;107(6):1313-1320.16909424
134 Gordon HS, Pugach O, Berbaum ML, Ford ME. Examining patients' trust in physicians and the VA healthcare system in a prospective cohort followed for six-months after an exacerbation of heart failure. Patient Educ. Couns. 2014;97(2):173-179.25088616
135 Graham-Steed T, Uchio E, Wells CK, Aslan M, Ko J, Concato J. ‘Race’ and prostate cancer mortality in equal-access healthcare systems. Am. J. Med. 2013;126(12):1084-1088.24262722
136 Groeneveld PW, Kruse GB, Chen Z, Asch DA. Variation in cardiac procedure use and racial disparity among Veterans Affairs Hospitals. Am. Heart J. 2007;153(2):320-327.17239696
137 Grubaugh AL, Frueh BC, Elhai JD, Monnier J, Knapp RG, Magruder KM. Racial Differences in Psychiatric Symptom Patterns and Service Use in VA Primary Care Clinics. Psychiatr. Serv. 2006;57(3):410-413.16525003
138 Grubaugh AL, Slagle DM, Long M, Frueh BC, Magruder KM. Racial disparities in trauma exposure, psychiatric symptoms, and service use among female patients in Veterans Affairs primary care clinics. Womens Health Issues. 2008;18(6):433-441.19041595
139 Grubaugh AL, Elhai JD, Ruggiero KJ, Egede LE, Naifeh JA, Frueh BC. Equity in Veterans Affairs disability claims adjudication in a national sample of veterans. Mil. Med. 2009;174(12):1241-1246.20055063
140 Halanych JH, Wang F, Miller DR, . Racial/Ethnic Differences in Diabetes Care for Older Veterans: Accounting for Dual Health System Use Changes Conclusions. Med. Care. May 2006;44(5):439-445.16641662
141 Haskell SG, Bean-Mayberry B, Goulet JL, Skanderson M, Good CB, Justice AC. Determinants of hormone therapy discontinuation among female veterans nationally. Mil. Med. 2008;173(1):91-96.18251338
142 Haskell SG, Brandt CA, Krebs EE, Skanderson M, Kerns RD, Goulet JL. Pain among veterans of Operations Enduring Freedom and Iraqi Freedom: Do women and men differ? Pain Med. Oct 2009;10(7):1167-1173.19818028
143 Hausmann LRM, Mor M, Hanusa BH, . The effect of patient race on total joint replacement recommendations and utilization in the orthopedic setting. J. Gen. Intern. Med. 2010;25(9):982-988.20509053
144 Hausmann LRM, Hanusa BH, Kresevic DM, . Orthopedic communication about osteoarthritis treatment: Does patient race matter? Arthritis Care Res. 2011;63(5):635-642.
145 Hausmann LRM, Gao S, Lee ES, Kwoh CK. Racial disparities in the monitoring of patients on chronic opioid therapy. Pain. 2013;154(1):46-52.23273103
146 Hausmann LRM, Gao S, Mor MK, Schaefer JH, Jr., Fine MJ. Understanding racial and ethnic differences in patient experiences with outpatient health care in Veterans Affairs Medical Centers. Med. Care. 2013;51(6):532-539.23673395
147 Hausmann LRM, Gao S, Mor MK, Schaefer JH, Jr.,Fine MJ. Patterns of sex and racial/ethnic differences in patient health care experiences in US Veterans Affairs hospitals. Med. Care. 2014;52(4):328-335.24848206
148 Heidenreich P. Disparities in VA Heart Failure Care. HSR&D study (RRP 08-236). 2009; http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141699487. Accessed November 14, 2016.
149 Higgins DM, Kerns RD, Brandt CA, . Persistent pain and comorbidity among Operation Enduring Freedom/Operation Iraqi Freedom/operation New Dawn veterans. Pain medicine (Malden, Mass.). 2014;15(5):782-790.
150 Hope OA, Zeber JE, Kressin NR, . New-onset geriatric epilepsy care: Race, setting of diagnosis, and choice of antiepileptic drug. Epilepsia. 2009;50(5):1085-1093.19054416
151 Horner RD, Leonard AC. Factors associated with a provider's recommendation of carotid endarterectomy: implications for understanding disparities in the use of invasive procedures. J. Vasc. Surg. 2007;45(1):124-129.17210396
152 Hou JK, Kramer JR, Richardson P, Sansgiry S, El-Serag HB. Myelosuppression monitoring after immunomodulator initiation in veterans with inflammatory bowel disease: a national practice audit. Aliment. Pharmacol. Ther. 2012;36(11-12):1049-1056.23061548
153 Hou JK, Kramer JR, Richardson P, Mei M, El-Serag HB. Risk of colorectal cancer among Caucasian and African American veterans with ulcerative colitis. Inflamm. Bowel Dis. 2012;18(6):1011-1017.22334479
154 Hudson MLA, Luo S, Chrusciel T, . Do racial disparities exist in the use of prostate cancer screening and detection tools in veterans? Urol. Oncol. 2014;32(1):34.e39-18.
155 Hunt KJ, Gebregziabher M, Lynch CP, Echols C, Mauldin PD, Egede LE. Impact of diabetes control on mortality by race in a national cohort of veterans. Ann. Epidemiol. 2013;23(2):74-79.23238350
156 Ibrahim SA, Stone RA, Cohen PZ, Henderson WG, Khuri SF, Kwoh CK. Race, ethnicity and length of hospital stay after knee or hip arthroplasty. Curr. Orthop. Pract. 2008;19(5):556-563.
157 Ilgen MA, Downing K, Zivin K, . Exploratory data mining analysis identifying subgroups of patients with depression who are at high risk for suicide. J. Clin. Psychiatry. 2009;70(11):1495-1500.20031094
158 Irmiter C, McCarthy JF, Barry KL, Soliman S, Blow FC. Reinstitutionalization following psychiatric discharge among VA patients with serious mental illness: a national longitudinal study. Psychiatr. Q. 2007;78(4):279-286.17763982
159 Jha AK, Stone R, Lave J, Chen H, Klusaritz H, Volpp K. The concentration of hospital care for black veterans in Veterans Affairs hospitals: implications for clinical outcomes. J. Healthc. Qual. 2010;32(6):52-61.20946426
160 Jia H, Chumbler NR, Wang X, . Racial and ethnic disparities in post-stroke depression detection. Int. J. Geriatr. Psychiatry. 2010;25(3):298-304.19637399
161 Jones L, Sin M, Hage F, . Characteristics and outcomes of patients with advanced chronic systolic heart failure receiving care at the Veterans Affairs versus other hospitals: insights from the Beta-blocker Evaluation of Survival Trial (BEST). Circ. Heart Fail. 2015;8(1):17-24.25480782
162 Kales HC, Kim HM, Austin KL, Valenstein M. Who receives outpatient monitoring during high-risk depression treatment periods? J. Am. Geriatr. Soc. 2010;58(5):908-913.20406321
163 Kalkonde YV, Pinto-Patarroyo GP, Goldman T, . Ethnic disparities in the treatment of dementia in veterans. Dement. Geriatr. Cogn. Disord. 2009;28(2):145-152.19690417
164 Kamalesh M, Shen J, Tierney WM. Stroke mortality and race: does access to care influence outcomes? Am. J. Med. Sci. 2007;333(6):327-332.17570984
165 Kazerooni R, Takizawa A, Vu K. Predictors of adherence to hormonal contraceptives in a female veteran population. Contraception. Apr 2014;89(4):292-298.24457062
166 Keyhani S, Cheng EM, Ofner S, Williams LS, Halm EA, Bravata DM. The Underuse of Interventions in Veterans With Symptomatic Carotid Stenosis. Am. J. Manag. Care. 2014;20(7):e250-256.25295544
167 Kilbourne AM, Salloum I, Dausey D, . Quality of care for substance use disorders in patients with serious mental illness. J. Subst. Abuse Treat. 2006;30(1):73-77.16377454
168 Kilbourne AM, McCarthy JF, Himelhoch S, Welsh D, Hauser P, Blow FC. Guideline-concordant hepatitis C virus testing and notification among patients with and without mental disorders. Gen. Hosp. Psychiatry. 2008;30(6):495-500.19061674
169 Kilbourne AM, Welsh D, McCarthy JF, Post EP, Blow FC. Quality of care for cardiovascular disease-related conditions in patients with and without mental disorders. J. Gen. Intern. Med. 2008;23(10):1628-1633.18626722
170 Kimerling R, Pavao J, Valdez C, Mark H, Hyun JK, Saweikis M. Military sexual trauma and patient perceptions of Veteran Health Administration health care quality. Womens Health Issues. 2011;21(4 Suppl):S145-151.21724134
171 Kokkinos P, Myers J, Nylen E, . Exercise capacity and all-cause mortality in African American and Caucasian men with type 2 diabetes. Diabetes Care. 2009;32(4):623-628.19196898
172 Koo KH, Madden E, Maguen S. Race-ethnicity and gender differences in VA health care service utilization among US veterans of recent conflicts. Psychiatr. Serv. 2015.
173 Koscuiszka M, Hatcher D, Christos PJ, . Impact of race on survival in patients with clinically nonmetastatic prostate cancer who deferred primary treatment. Cancer. 2012;118(12):3145-3152.22020835
174 Koshiol J, Lam TK, Gridley G, Check D, Brown LM, Landgren O. Racial differences in chronic immune stimulatory conditions and risk of non-Hodgkin's lymphoma in veterans from the United States. J. Clin. Oncol. 2011;29(4):378-385.21172877
175 Kovesdy CP, Quarles LD, Lott EH, . Survival advantage in black versus white men with CKD: effect of estimated GFR and case mix. Am. J. Kidney Dis. 2013;62(2):228-235.23369826
176 Kovesdy CP, Norris KC, Boulware LE, . Association of race with mortality and cardiovascular events in a large cohort of US veterans. Circulation. 2015;132(16):1538-1548.26384521
177 Kressin NR, Glickman ME, Peterson ED, Whittle J, Orner MB, Petersen LA. Functional status outcomes among white and African-American cardiac patients in an equal access system. Am. Heart J. 2007;153(3):418-425.17307422
178 Kressin NR, Wang F, Long J, . Hypertensive patients' race, health beliefs, process of care, and medication adherence. J. Gen. Intern. Med. 2007;22(6):768-774.17364243
179 Landrum L. Race and income association with health service utilization for veterans with heart failure. Augusta, GA: Nursing Science, Georgia Health Sciences University; 2012.
180 Landrum MB, Keating NL, Lamont EB, Bozeman SR, McNeil BJ. Reasons for underuse of recommended therapies for colorectal and lung cancer in the Veterans Health Administration. Cancer. 2012;118(13):3345-3355.22072536
181 Liang MK, Li LT, Avellaneda A, Moffett JM, Hicks SC, Awad SS. Outcomes and predictors of incisional surgical site infection in stoma reversal. JAMA Surgery. Feb 2013;148(2):183-189.23426597
182 Luca SM, Blosnich JR, Hentschel EAW, King E, Amen S. Mental health care utilization: how race, ethnicity and veteran status are associated with seeking help. Community Ment. Health J. 2016;52(2):174-179.26659853
183 Luncheon C, Zack M. Health-related quality of life among US veterans and civilians by race and ethnicity. Prev. Chronic Dis. 2012;9(101205018):E108.22652126
184 Lynch CP, Gebregziabher M, Echols C, Gilbert GE, Zhao Y, Egede LE. Racial disparities in all-cause mortality among veterans with type 2 diabetes. J. Gen. Intern. Med. 2010;25(10):1051-1056.20532659
185 Lynch CP, Gebregziabher M, Axon R, Hunt KE, Payne E, Egede LE. Geographic and racial/ethnic variations in patterns of multimorbidity burden in patients with type 2 diabetes. J. Gen. Intern. Med. Jan 2015;30(1):25-32.25127728
186 Mackenzie TA, Wallace AE, Weeks WB. Impact of rural residence on survival of male veterans affairs patients after age 65. J. Rural Health. 2010;26(4):318-324.21029166
187 Mattocks K, Kroll-Desrosiers A, Zephyrin L, . Infertility care among OEF/OIF/OND women veterans in the Department of Veterans Affairs. Med. Care. Apr 2015;53(4s1):S68-S75.25767979
188 May FP, Bromley EG, Reid MW, . Low uptake of colorectal cancer screening among African Americans in an integrated Veterans Affairs health care network. Gastrointest. Endosc. 2014;80(2):291-298.24674351
189 Maynard C, Sun H, Lowy E, Sales AE, Fihn SD. The use of percutaneous coronary intervention in black and white veterans with acute myocardial infarction. BMC Health Serv. Res. 2006;6(101088677):107.16923183
190 Mehta JL, Bursac Z, Mehta P, . Racial disparities in prescriptions for cardioprotective drugs and cardiac outcomes in Veterans Affairs Hospitals. Am. J. Cardiol. 2010;105(7):1019-1023.20346324
191 Merkow RP, Bilimoria KY, Sherman KL, McCarter MD, Gordon HS, Bentrem DJ. Efficiency of colorectal cancer care among veterans: analysis of treatment wait times at Veterans Affairs Medical Centers. J. Oncol. Pract. 2013;9(4):e154-163.23942933
192 Merriman NA, Porter SB, Brensinger CM, Reddy KR, Chang K-M. Racial difference in mortality among U.S. veterans with HCV/HIV coinfection. Am. J. Gastroenterol. 2006;101(4):760-767.16494582
193 Meyers JF, Robbins AS, Gildengorin GL, Grayson JK. Racial differences in mortality among men hospitalized in military hospitals. Mil. Med. 2008;173(6):539-543.18595416
194 Moore CD, Gao K, Shulan M. Racial, income, and marital status disparities in hospital readmissions within a veterans-integrated health care network. Eval. Health Prof. 2015;38(4):491-507.23811693
195 Morasco BJ, Duckart JP, Carr TP, Deyo RA, Dobscha SK. Clinical characteristics of veterans prescribed high doses of opioid medications for chronic non-cancer pain. PAIN®. 2010;151(3):625-632.20801580
196 Morikawa A, Varma V, Gillespie TW, . Counting alleles in single lesions of prostate tumors from ethnically diverse patients. Prostate. 2008;68(3):231-240.18092351
197 Myaskovsky L, Doebler DA, Posluszny DM, . Perceived discrimination predicts longer time to be accepted for kidney transplant. Transplantation. 2012;93(4):423.22228417
198 Nguyen TH, Thrift AP, Ramsey D, . Risk factors for Barrett's esophagus compared between African Americans and non-Hispanic Whites. Am. J. Gastroenterol. 2014;109(12):1870-1880.25420546
199 Peiris AN, Bailey BA, Peiris P, Copeland RJ, Manning T. Race and vitamin D status and monitoring in male veterans. J. Natl. Med. Assoc. 2011;103(6):492-497.21830632
200 Phillips KL, Copeland LA, Zeber JE, Stock EM, Tsan JY, MacCarthy AA. Racial/ethnic disparities in monitoring metabolic parameters for patients with schizophrenia receiving antipsychotic medications. Am. J. Geriatr. Psychiatry. 2015;23(6):596-606.25154537
201 Polsky D, Lave J, Klusaritz H, . Is lower 30-day mortality posthospital admission among Blacks unique to the veterans affairs health care system? Med. Care. 2007;45(11):1083-1089.18049349
202 Polsky D, Jha AK, Lave J, . Short- and long-term mortality after an acute illness for elderly whites and blacks. Health Serv. Res. 2008;43(4):1388-1402.18355259
203 Poon I, Lal LS, Ford ME, Braun UK. Racial/ethnic differences in blood pressure control and medication utilization in a cohort of older Veterans with dementia. Am. J. Ther. 2010;17(1):34-41.19535967
204 Poon I, Lal LS, Ford ME, Braun UK. Racial/ethnic disparities in medication use among veterans with hypertension and dementia: a national cohort study. Ann. Pharmacother. 2009;43(2):185-193.19193586
205 Pugh MJ, Hanlon JT, Zeber JE, Bierman A, Cornell J, Berlowitz DR. Assessing potentially inappropriate prescribing in the elderly Veterans Affairs population using the HEDIS 2006 quality measure. J. Manag. Care Pharm. Sep 2006;12(7):537-545.16981799
206 Pugh MJV, Rosen AK, Montez-Rath M, . Potentially inappropriate prescribing for the elderly: effects of geriatric care at the patient and health care system level. Med. Care. 2008;46(2):167-173.18219245
207 Pugh MJV, Hanlon JT, Wang C-P, . Trends in use of high-risk medications for older veterans: 2004 to 2006. J. Am. Geriatr. Soc. 2011;59(10):1891-1898.21883108
208 Quinones AR, Thielke SM, Beaver KA, Trivedi RB, Williams EC, Fan VS. Racial and ethnic differences in receipt of antidepressants and psychotherapy by veterans with chronic depression. Psychiatric services (Washington, D.C.). 2014;65(2):193-200.
209 Rawaf MM, Kressin NR. Exploring racial and sociodemographic trends in physician behavior, physician trust and their association with blood pressure control. J. Natl. Med. Assoc. 2007;99(11):1248-1254.18020100
210 Richardson L, Egede L, Mueller M. Effect of race/ethnicity and persistent recognition of depression on mortality in elderly men with type 2 diabetes and depression. Diabetes Care. 2008;31(5):880-881.18332155
211 Robinson CN, Balentine CJ, Marshall CL, . Ethnic disparities are reduced in VA colon cancer patients. Am. J. Surg. 2010;200(5):636-639.21056144
212 Rogers TJ, Smith BM, Weaver FM, . Healthcare utilization following mild traumatic brain injury in female veterans. Brain Inj. 2014;28(11):1406-1412.24945602
213 Rose DE, Farmer MM, Yano EM, Washington DL. Racial/ethnic differences in cardiovascular risk factors among women veterans. J. Gen. Intern. Med. Jul 2013;28 Suppl 2:S524-528.23807060
214 Rosen MI, Afshartous DR, Nwosu S, . Racial differences in veterans' satisfaction with examination of disability from posttraumatic stress disorder. Psychiatric services (Washington, D.C.). 2013;64(4):354-359.
215 Roumie CL, Ofner S, Ross JS, . Prevalence of inadequate blood pressure control among veterans after acute ischemic stroke hospitalization: a retrospective cohort. Circ. Cardiovasc. Qual. Outcomes. 2011;4(4):399-407.21693725
216 Sabounchi S, Keihanian S, Anand BS. Impact of race on colorectal cancer. Clin. Colorectal Cancer. 2012;11(1):66-70.21729674
217 Sajatovic M, Valenstein M, Blow F, Ganoczy D, Ignacio R. Treatment adherence with lithium and anticonvulsant medications among patients with bipolar disorder. Psychiatric services (Washington, D.C.). 2007;58(6):855-863.
218 Sambamoorthi U, Shen C, Findley P, Frayne S, Banerjea R. Depression treatment patterns among women veterans with cardiovascular conditions or diabetes. World Psychiatry. 2010;9(3):177-182.20975865
219 Sambamoorthi U, Mitra S, Findley PA, Pogach LM. Decomposing gender differences in low-density lipoprotein cholesterol among veterans with or at risk for cardiovascular illness. Womens Health Issues. Mar 2012;22(2):e201-208.22133598
220 Samuel CA, Landrum MB, McNeil BJ, Bozeman SR, Williams CD, Keating NL. Racial Disparities in Cancer Care in the Veterans Affairs Health Care System and the Role of Site of Care. Am. J. Public Health. Sep 2014;104(Suppl 4):S562-571.25100422
221 Sandulache VC, Kubik MW, Skinner HD, Malsky JA, Gelbard AH, Zevallos JP. Impact of race/ethnicity on laryngeal cancer in patients treated at a Veterans Affairs Medical Center. Laryngoscope. 2013;123(9):2170-2175.23729204
222 Sarrazin MV, Cannon KT, Rosenthal GE, Kaldjian LC. Racial differences in mortality among veterans hospitalized for exacerbation of chronic obstructive pulmonary disease. J. Natl. Med. Assoc. 2009;101(7):656-662.19634586
223 Schreiber D, Levy EB, Schwartz D, . Impact of race in a predominantly African-American population of patients with low/intermediate risk prostate cancer undergoing radical prostatectomy within an equal access care institution. Int. Urol. Nephrol. 2014;46(10):1941-1946.24969031
224 Schwartz SW, Sebastiao Y, Rosas J, Iannacone MR, Foulis PR, Anderson WM. Racial disparity in adherence to positive airway pressure among US veterans. Sleep Breath. Jan 25 2016.
225 Seal KH, Bertenthal D, Miner CR, Sen S, Marmar C. Bringing the war back home: Mental health disorders among 103 788 US veterans returning from Iraq and Afghanistan seen at Department of Veterans Affairs Facilities. Arch. Intern. Med. 2007;167(5):476-482.17353495
226 Seal KH, Cohen G, Waldrop A, Cohen BE, Maguen S, Ren L. Substance use disorders in Iraq and Afghanistan veterans in VA healthcare, 2001-2010: Implications for screening, diagnosis and treatment. Drug Alcohol Depend. Jul 1 2011;116(1-3):93-101.21277712
227 Shaw J, Asch S, Kimerling R, Frayne S, Shaw K, Phibbs C. Posttraumatic stress disorder and risk of spontaneous preterm birth. Obstet. Gynecol. 2014;124(6):1111-1119.25415162
228 Shimada SL, Montez-Rath ME, Loveland SA, Zhao S, Kressin NR, Rosen AK Advances in Patient Safety: Racial Disparities in Patient Safety Indicator (PSI) Rates in the Veterans Health Administration. Rockville (MD): Agency for Healthcare Research and Quality;2008.
229 Shimada SL, Montez-Rath ME, Loveland SA, Zhao S, Kressin NR, Rosen AK. Racial disparities in patient safety indicator (PSI) rates in the Veterans Health Administration. 2008.
230 Spoont MR, Hodges J, Murdoch M, Nugent S. Race and ethnicity as factors in mental health service use among veterans with PTSD. J. Trauma. Stress. 2009;22(6):648-653.19921734
231 Spoont MR, Nelson DB, Murdoch M, . Are there racial/ethnic disparities in VA PTSD treatment retention? Depress. Anxiety. 2015;32(6):415-425.25421265
232 Taber DJ, Gebregziabher M, Payne EH, Srinivas T, Baliga PK, Egede LE. Overall Graft Loss Versus Death-Censored Graft Loss: Unmasking the Magnitude of Racial Disparities in Outcomes Among US Kidney Transplant Recipients. Transplantation. Feb 19 2016.
233 Tiwari A, Rajan M, Miller D, Pogach L, Olfson M, Sambamoorthi U. Guideline-consistent antidepressant treatment patterns among veterans with diabetes and major depressive disorder. Psychiatric services (Washington, D.C.). 2008;59(10):1139-1147.
234 Trivedi AN, Grebla RC, Wright SM, Washington DL. Despite improved quality of care in the Veterans Affairs health system, racial disparity persists for important clinical outcomes. Health affairs (Project Hope). 2011;30(4):707-715.21471492
235 Tsai J, Desai MU, Cheng AW, Chang J. The effects of race and other socioeconomic factors on health service use among American military veterans. Psychiatr. Q. 2014;85(1):35-47.23949577
236 Tseng C-L, Sambamoorthi U, Tiwari A, Rajan M, Findley P, Pogach L. Diabetes care among veteran women with disability. Womens Health Issues. 2006;16(6):361-371.17188219
237 Tseng C-L, Sambamoorthi U, Helmer D, . The association between mental health functioning and nontraumatic lower extremity amputations in veterans with diabetes. Gen. Hosp. Psychiatry. 2007;29(6):537-546.18022047
238 Tseng CL, Rajan M, Miller DR, Lafrance JP, Pogach L. Trends in initial lower extremity amputation rates among Veterans Health Administration health care System users from 2000 to 2004. Diabetes Care. May 2011;34(5):1157-1163.21411510
239 Twombly JG, Long Q, Zhu M, . Diabetes care in black and white veterans in the southeastern U.S. Diabetes Care. 2010;33(5):958-963.20103548
240 Vimalananda VG, Miller DR, Christiansen CL, Wang W, Tremblay P, Fincke BG. Cardiovascular disease risk factors among women veterans at VA medical facilities. J. Gen. Intern. Med. Jul 2013;28 Suppl 2:S517-523.23807059
241 Volpp K, Stone R, Lave J, . Is thirty-day hospital mortality really lower for black veterans compared with white veterans? Health Serv. Res. 2007;42(4):1613-1631.17610440
242 Washington D Women Veterans Ambulatory Care Use Project, Phase II. HSR&D study (IAE 06-083). 2009; http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141696839. Accessed November 14, 2016.
243 Washington D VA Facility Determinants of Racial-Ethnic Variations in Quality of Care. HSR&D study (IAA 08-087). 2011; http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141699658. Accessed November 14, 2016.
244 Wendel CS, Shah JH, Duckworth WC, Hoffman RM, Mohler MJ, Murata GH. Racial and ethnic disparities in the control of cardiovascular disease risk factors in Southwest American veterans with type 2 diabetes: the Diabetes Outcomes in Veterans Study. BMC Health Serv. Res. 2006;6(101088677):58.16716235
245 Whittle J, Kressin NR, Peterson ED, . Racial differences in prevalence of coronary obstructions among men with positive nuclear imaging studies. J. Am. Coll. Cardiol. May 16 2006;47(10):2034-2041.16697322
246 Whittle J. Better hypertension and lipid care in racially diverse, veterans at risk. HSR&D study (RRP 09-123). 2011; http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141699715. Accessed November 14, 2016.
247 Williams CD, Stechuchak KM, Zullig LL, Provenzale D, Kelley MJ. Influence of comorbidity on racial differences in receipt of surgery among US veterans with early-stage non-small-cell lung cancer. J. Clin. Oncol. 2013;31(4):475-481.23269988
248 Yang JC, Huang D, Hser Y-I. Long-term morbidity and mortality among a sample of cocaine-dependent black and white veterans. J. Urban Health. 2006;83(5):926-940.16775765
249 Zeber JE, McCarthy JF, Bauer MS, Kilbourne AM. Self-reported access to general medical and psychiatric care among veterans with bipolar disorder. Psychiatr. Serv. 2007;58(6):740.17535932
250 Zeber JE, Copeland LA, McCarthy JF, Bauer MS, Kilbourne AM. Perceived access to general medical and psychiatric care among veterans with bipolar disorder. Am. J. Public Health. 2009;99(4):720-727.19150912
251 Zeber JE, Miller AL, Copeland LA, . Medication adherence, ethnicity, and the influence of multiple psychosocial and financial barriers. Adm. Policy Ment. Health. 2011;38(2):86-95.20549327
252 Zevallos JP, Sandulache VC, Hamblin J, . Impact of race on oropharyngeal squamous cell carcinoma presentation and outcomes among veterans. Head Neck. Jan 2016;38(1):44-50.24992520
253 Zickmund S. Racial and Ethnic Disparities in Satisfaction with VA Care. HSR&D study (IIR 10-144). 2015; http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141701664. Accessed November 14, 2016.
254 Zivin K, Kim HM, McCarthy JF, . Suicide mortality among individuals receiving treatment for depression in the Veterans Affairs health system: Associations with patient and treatment setting characteristics. Am. J. Public Health. 2007;97(12):2193-2198.17971541
255 Zullig LL, Jackson GL, Weinberger M, Provenzale D, Reeve BB, Carpenter WR. An examination of racial differences in process and outcome of colorectal cancer care quality among users of the veterans affairs health care system. Clin. Colorectal Cancer. 2013;12(4):255-260.23988481
256 Zullig LL, Carpenter WR, Provenzale D, Weinberger M, Reeve BB, Jackson GL. Examining potential colorectal cancer care disparities in the Veterans Affairs health care system. J. Clin. Oncol. 2013;31(28):3579-3584.24002515
257 Zullig LL, Carpenter WR, Provenzale DT, . The association of race with timeliness of care and survival among Veterans Affairs health care system patients with late-stage non-small cell lung cancer. Cancer Manag. Res. 2013;5(101512700):157-163.23900515
258 Jackson GL, Weinberger M, Hamilton NS, Edelman D. Racial/ethnic and educational-level differences in diabetes care experiences in primary care. Prim. Care Diabetes. 2008;2(1):39-44.18684419
259 Alvord LA, Henderson WG, Benton K, Buchwald D. Surgical outcomes in American Indian veterans: a closer look. J. Am. Coll. Surg. 2009;208(6):1085-1092. e1081.19476896
260 Johnson PJ, Carlson KF, Hearst MO. Healthcare disparities for American Indian veterans in the United States: a population-based study. Med. Care. 2010;48(6):563-569.20473210
261 Kaufman CE, Brooks E, Kaufmann LJ, . Rural native veterans in the Veterans Health Administration: characteristics and service utilization patterns. J. Rural Health. 2013;29(3):304-310.23802932
262 Tsai J, Whealin JM, Pietrzak RH. Asian American and Pacific Islander Military Veterans in the United States: Health Service Use and Perceived Barriers to Mental Health Services. Am. J. Public Health. Sep 2014;104(Suppl 4):S538-547.25100419
263 Aliaga P. Mental health encounters and diagnoses following deployment to Iraq and/or Afghanistan, US Armed Forces, 2001–2006. Med Surveill Mon Rep. 2007;14(4):2-8.
264 Bernardy NC, Lund BC, Alexander B, Jenkyn AB, Schnurr PP, Friedman MJ. Gender differences in prescribing among veterans diagnosed with posttraumatic stress disorder. J. Gen. Intern. Med. Jul 2013;28 Suppl 2:S542-548.23807063
265 Blackstock OJ, Tate JP, Akgun KM, . Sex disparities in overall burden of disease among HIV-infected individuals in the Veterans Affairs healthcare system. J. Gen. Intern. Med. Jul 2013;28 Suppl 2:S577-582.23807068
266 Borrero S, Kwoh CK, Sartorius J, Ibrahim SA. Brief report: Gender and total knee/hip arthroplasty utilization rate in the VA system. J. Gen. Intern. Med. Mar 2006;21 Suppl 3:S54-57.16637947
267 Burnett-Zeigler I, Zivin K, Ilgen MA, Islam K, Bohnert ASB. Perceptions of quality of health care among veterans with psychiatric disorders. Psychiatr. Serv. 2011;62(9):1054-1059.21885584
268 Carlson KF, Taylor BC, Hagel EM, Cutting A, Kerns R, Sayer NA. Headache diagnoses among Iraq and Afghanistan war veterans enrolled in VA: a gender comparison. Headache. Nov-Dec 2013;53(10):1573-1582.24102376
269 Chatterjee S, Rath ME, Spiro A, III, Eisen S, Sloan KL, Rosen AK. Gender differences in veterans health administration mental health service use: Effects of age and psychiatric diagnosis. Womens Health Issues. 2009;19(3):176-184.19447322
270 Cohen BE, Gima K, Bertenthal D, Kim S, Marmar CR, Seal KH. Mental health diagnoses and utilization of VA non-mental health medical services among returning Iraq and Afghanistan veterans. J. Gen. Intern. Med. 2010;25(1):18-24.
271 Currie S An investigation of the quantity and type of female veterans' responses to hepatitis C treatment screening and acceptance. San Francisco, CA: The Faculty of the School of Education Learning and Instruction Department, The University of San Francisco; 2008.
272 Curry JF, Aubuchon-Endsley N, Brancu M, Runnals JJ, Fairbank JA. Lifetime major depression and comorbid disorders among current-era women veterans. J. Affect. Disord. Jan 2014;152-154:434-440.24210623
273 Davis TD, Deen TL, Fortney JC, Sullivan G, Hudson TJ. Utilization of VA mental health and primary care services among Iraq and Afghanistan veterans with depression: the influence of gender and ethnicity status. Mil. Med. 2014;179(5):515-520.24806496
274 Desai MM, Rosenheck RA, Craig TJ. Case-finding for depression among medical outpatients in the Veterans Health Administration. Med. Care. Feb 2006;44(2):175-181.16434917
275 Doran KM, Raven MC, Rosenheck RA. What drives frequent emergency department use in an integrated health system? National data from the Veterans Health Administration. Ann. Emerg. Med. 2013;62(2):151-159.23582617
276 Duggal M, Goulet JL, Womack J, . Comparison of outpatient health care utilization among returning women and men Veterans from Afghanistan and Iraq. BMC Health Serv. Res. 2010;10:175.20565985
277 Eisen SV, Schultz MR, Vogt D, . Mental and physical health status and alcohol and drug use following return from deployment to Iraq or Afghanistan. Am. J. Public Health. Mar 2012;102 Suppl 1:S66-73.22390605
278 Ersek M, Smith D, Cannuscio C, Richardson DM, Moore D. A nationwide study comparing end-of-life care for men and women veterans. J. Palliat. Med. 2013;16(7):734-740.23676096
279 Farmer MM, Rose DE, Riopelle D, Lanto AB, Yano EM. Gender differences in smoking and smoking cessation treatment: an examination of the organizational features related to care. Womens Health Issues. 2011;21(4 Suppl):S182-189.21724139
280 Fasoli DR, Glickman ME, Eisen SV. Predisposing characteristics, enabling resources and need as predictors of utilization and clinical outcomes for veterans receiving mental health services. Med. Care. 2010;48(4):288-295.20355260
281 Fontana A, Rosenheck R, Desai R. Female veterans of Iraq and Afghanistan seeking care from VA specialized PTSD programs: Comparison with male veterans and female war zone veterans of previous eras. J. Womens Health. 2010;19(4):751-757.
282 Frayne SM, Parker VA, Christiansen CL, . Health status among 28,000 women veterans. The VA Women's Health Program Evaluation Project. J. Gen. Intern. Med. Mar 2006;21 Suppl 3:S40-46.
283 Frayne SM, Yu W, Yano EM, . Gender and use of care: planning for tomorrow's Veterans Health Administration. J Womens Health (Larchmt). Oct 2007;16(8):1188-1199.17937572
284 Freedy JR, Magruder KM, Mainous AG, Frueh BC, Geesey ME, Carnemolla M. Gender differences in traumatic event exposure and mental health among veteran primary care patients. Mil. Med. 2010;175(10):750-758.20968265
285 Garfield LD, Scherrer JF, Chrusciel T, . Factors associated with receipt of adequate antidepressant pharmacotherapy by VA patients with recurrent depression. Psychiatric services (Washington, D.C.). 2011;62(4):381-388.
286 Gellad ZF, Stechuchak KM, Fisher DA, . Longitudinal adherence to fecal occult blood testing impacts colorectal cancer screening quality. Am. J. Gastroenterol. 2011;106(6):1125-1134.21304501
287 Griffin JM, Burgess D, Vernon SW, . Are gender differences in colorectal cancer screening rates due to differences in self-reporting? Prev. Med. 2009;49(5):436-441.19765609
288 Harris AH, Bradley KA, Bowe T, Henderson P, Moos R. Associations between AUDIT-C and mortality vary by age and sex. Popul Health Manag. Oct 2010;13(5):263-268.20879907
289 Haskell S, Gordon K, Mattocks K, . Gender differences in rates of depression, PTSD, pain, obesity, and military sexual trauma among Connecticut War Veterans of Iraq and Afghanistan. J Womens Health (Larchmt). 2010;19(2):267-271.20109115
290 Haskell SG, Mattocks K, Goulet JL, . The burden of illness in the first year home: Do male and female VA users differ in health conditions and healthcare utilization. Womens Health Issues. 2011;21(1):92-97.21185994
291 Haskell SG, Bathulapalli H, Pham T, . Sex differences in patient and provider response to elevated low-density lipoprotein cholesterol. Womens Health Issues. 2014;24(5):575-580.25213750
292 Hawkins EJ, Lapham GT, Kivlahan DR, Bradley KA. Recognition and management of alcohol misuse in OEF/OIF and other veterans in the VA: a cross-sectional study. Drug Alcohol Depend. 2010;109(1):147-153.20167440
293 Hawkins EJ, Malte CA, Baer JS, Kivlahan DR. Prevalence, predictors, and service utilization of patients with recurrent use of Veterans Affairs substance use disorder specialty care. J. Subst. Abuse Treat. 2012;43(2):221-230.22197302
294 Hoffmire CA, Kemp JE, Bossarte RM. Changes in suicide mortality for veterans and nonveterans by gender and history of VHA service use, 2000-2010. Psychiatr. Serv. 2015;66(9):959-965.25930036
295 Hundt NE, Barrera TL, Mott JM, . Predisposing, enabling, and need factors as predictors of low and high psychotherapy utilization in veterans. Psychol. Serv. 2014;11(3):281-289.24841513
296 Ilgen MA, Bohnert ASB, Ignacio RV, . Psychiatric diagnoses and risk of suicide in veterans. Arch. Gen. Psychiatry. 2010;67(11):1152-1158.21041616
297 Iverson KM, Hendricks AM, Kimerling R, . Psychiatric diagnoses and neurobehavioral symptom severity among OEF/OIF VA patients with deployment-related traumatic brain injury: a gender comparison. Womens Health Issues. 2011;21(4):S210-S217.21724143
298 Kaur S, Stechuchak KM, Coffman CJ, Allen KD, Bastian LA. Gender differences in health care utilization among veterans with chronic pain. J. Gen. Intern. Med. Feb 2007;22(2):228-233.17356991
299 Leslie DL, Goulet J, Skanderson M, Mattocks K, Haskell S, Brandt C. VA health care utilization and costs among male and female veterans in the year after service in Afghanistan and Iraq. Mil. Med. 2011;176(3):265-269.21456351
300 Lund BC, Bernardy NC, Vaughan-Sarrazin M, Alexander B, Friedman MJ. Patient and facility characteristics associated with benzodiazepine prescribing for veterans with PTSD. Psychiatr. Serv. 2013;64(2):149-155.23154834
301 Maguen S, Ren L, Bosch JO, Marmar CR, Seal KH. Gender differences in mental health diagnoses among Iraq and Afghanistan veterans enrolled in veterans affairs health care. Am. J. Public Health. 2010;100(12):2450-2456.20966380
302 Montgomery AE, Byrne TH. Services utilization among recently homeless veterans: a gender-based comparison. Mil. Med. 2014;179(3):236-239.24594455
303 Runnals JJ, Van Voorhees E, Robbins AT, . Self-reported pain complaints among Afghanistan/Iraq era men and women Veterans with comorbid posttraumatic stress disorder and major depressive disorder. Pain Med. Oct 2013;14(10):1529-1533.23924351
304 Sajatovic M, Bauer MS, Kilbourne AM, Vertrees JE, Williford W. Self-reported medication treatment adherence among veterans with bipolar disorder. Psychiatric services (Washington, D.C.). 2006;57(1):56-62.
305 Sayer NA, Hagel EM, Noorbaloochi S, . Gender differences in VA disability status for PTSD over time. Psychiatric services (Washington, D.C.). 2014;65(5):663-669.
306 Schwartz E, Charlotte M, Slade E, . Gender differences in antipsychotics prescribed to veterans with serious mental illness. Gen. Hosp. Psychiatry. Jul-Aug 2015;37(4):347-351.25936673
307 Seng EK, Driscoll MA, Brandt CA, . Prescription headache medication in OEF/OIF veterans: results from the Women Veterans Cohort Study. Headache. Sep 2013;53(8):1312-1322.23808756
308 Seyfried LS, Kales HC, Ignacio RV, Conwell Y, Valenstein M. Predictors of suicide in patients with dementia. Alzheimers Dement. 2011;7(6):567-573.22055973
309 Singh JA, Murdoch M. Effect of health-related quality of life on women and men's Veterans Affairs (VA) health care utilization and mortality. J. Gen. Intern. Med. Sep 2007;22(9):1260-1267.17610020
310 Street AE, Gradus JL, Giasson HL, Vogt D, Resick PA. Gender differences among veterans deployed in support of the wars in Afghanistan and Iraq. J. Gen. Intern. Med. 2013;28(2):556-562.
311 Teh CF, Kilbourne AM, McCarthy JF, Welsh D, Blow FC. Gender differences in health-related quality of life for veterans with serious mental illness. Psychiatr. Serv. Jun 2008;59(6):663-669.18511587
312 Tsai J, Kasprow WJ, Kane V, Rosenheck RA. National comparison of literally homeless male and female VA service users: entry characteristics, clinical needs, and service patterns. Womens Health Issues. 2014;24(1):e29-35.24342077
313 Tseng C-L, Sambamoorthi U, Rajan M, . Are there gender differences in diabetes care among elderly Medicare enrolled veterans? J. Gen. Intern. Med. 2006;21 Suppl 3(8605834):S47-53.16637945
314 Vimalananda VG, Miller DR, Palnati M, Christiansen CL, Fincke BG. Gender disparities in lipid-lowering therapy among veterans with diabetes. Womens Health Issues. 2011;21(4 Suppl):S176-181.21724138
315 Vimalananda VG, Miller DR, Hofer TP, Holleman RG, Klamerus ML, Kerr EA. Accounting for clinical action reduces estimates of gender disparities in lipid management for diabetic veterans. J. Gen. Intern. Med. Jul 2013;28 Suppl 2:S529-535.23807061
316 Virani S, Woodard L, Chitwood S, . Frequency and correlates of treatment intensification for elevated cholesterol levels in patients with cardiovascular disease. Am Heart J. 2011;162(4):725-732.e721.21982666
317 Virani SS, Woodard LD, Ramsey DJ, . Gender disparities in evidence-based statin therapy in patients with cardiovascular disease. Am. J. Cardiol. 2015;115(1):21-26.25456865
318 Vogt D, Vaughn R, Glickman ME, . Gender differences in combat-related stressors and their association with postdeployment mental health in a nationally representative sample of US OEF/OIF veterans. J. Abnorm. Psychol. 2011;120(4):797.21639595
319 Weimer M, Macey T, Nicolaidis C, Dobscha S, Duckart J, Morasco B. Sex differences in the medical care of VA patients with chronic non-cancer pain. Pain Med. 2013;14(12):1839-1847.23802846
320 Westermeyer J, Canive J, Thuras P, Thompson J, Crosby RD, Garrard J. A comparison of substance use disorder severity and course in American Indian male and female veterans. Am. J. Addict. 2009;18(1):87-92.19219670
321 Wheeler S, Bowen J, Maynard C, . Women veterans and outcomes after acute myocardial infarction. J Womens Health (Larchmt). 2009;18(5):613-618.19392640
322 Wright SM, Craig T, Campbell S, Schaefer J, Humble C. Patient satisfaction of female and male users of Veterans Health Administration services. J. Gen. Intern. Med. Mar 2006;21 Suppl 3:S26-32.16637941
323 Wright SM, Schaefer J, Reyes-Harvey E, Francis J Comparing the Care of Men and Women Veterans in the Department of Veterans Affairs. Washington, DC: Department of Veterans Affairs Office of Informatics & Analytics;2012.
324 Zinzow HM, Grubaugh AL, Frueh BC, Magruder KM. Sexual assault, mental health, and service use among male and female veterans seen in Veterans Affairs primary care clinics: a multi-site study. Psychiatry Res. May 30 2008;159(1-2):226-236.18423615
325 Ahmadi N, Hajsadeghi F, Mirshkarlo HB, Budoff M, Yehuda R, Ebrahimi R. Post-traumatic stress disorder, coronary atherosclerosis, and mortality. Am. J. Cardiol. 2011;108(1):29-33.21530936
326 Cohen LB, Taveira TH, Wu WC, Pirraglia PA. Maintenance of risk factor control in diabetic patients with and without mental health conditions after discharge from a cardiovascular risk reduction clinic. Ann. Pharmacother. Jul-Aug 2010;44(7-8):1164-1170.20501890
327 Copeland LA, Zeber JE, Sako EY, . Serious mental illnesses associated with receipt of surgery in retrospective analysis of patients in the Veterans Health Administration. BMC Surg. 2015;15(100968567):74.26084521
328 Dobie DJ, Maynard C, Kivlahan DR, . Posttraumatic stress disorder screening status is associated with increased VA medical and surgical utilization in women. J. Gen. Intern. Med. Mar 2006;21 Suppl 3:S58-64.
329 Frayne SM, Berg E, Holmes TH, . Mental illness-related disparities in length of stay: algorithm choice influences results. J. Rehabil. Res. Dev. 2010;47(8):709-718.21110246
330 Frayne SM, Chiu VY, Iqbal S, . Medical care needs of returning veterans with PTSD: their other burden. J. Gen. Intern. Med. 2011;26(1):33-39.20853066
331 Ganzini L, Socherman R, Duckart J, Shores M. End-of-life care for veterans with schizophrenia and cancer. Psychiatric services (Washington, D.C.). 2010;61(7):725-728.
332 Greenawalt DS, Copeland LA, MacCarthy AA, Sun FF, Zeber JE. Posttraumatic stress disorder and odds of major invasive procedures among U.S. Veterans Affairs patients. J. Psychosom. Res. 2013;75(4):386-393.24119948
333 Kaplowitz RA, Scranton RE, Gagnon DR, . Health care utilization and receipt of cholesterol testing by veterans with and those without mental illness. Gen. Hosp. Psychiatry. Mar-Apr 2006;28(2):137-144.16516064
334 Kilbourne AM, McCarthy JF, Post EP, . Access to and satisfaction with care comparing patients with and without serious mental illness. Int. J. Psychiatry Med. 2006;36(4):383-399.17407993
335 Kilbourne AM, Ignacio RV, Kim HM, Blow FC. Are VA patients with serious mental illness dying younger? Psychiatr. Serv. 2009;60(5):589.19411344
336 Kilbourne AM, Morden NE, Austin K, . Excess heart-disease-related mortality in a national study of patients with mental disorders: identifying modifiable risk factors. Gen. Hosp. Psychiatry. Nov-Dec 2009;31(6):555-563.19892214
337 Kodl MM, Powell AA, Noorbaloochi S, Grill JP, Bangerter AK, Partin MR. Mental health, frequency of healthcare visits, and colorectal cancer screening. Med. Care. 2010;48(10):934-939.20706162
338 Krein SL, Bingham CR, McCarthy JF, Mitchinson A, Payes J, Valenstein M. Diabetes treatment among VA patients with comorbid serious mental illness. Psychiatr. Serv. Jul 2006;57(7):1016-1021.16816287
339 Lehavot K, Der-Martirosian C, Simpson TL, Sadler AG, Washington DL. Barriers to care for women veterans with posttraumatic stress disorder and depressive symptoms. Psychol. Serv. 2013;10(2):203-212.23730964
340 Lynch CP, Gebregziabher M, Zhao Y, Hunt KJ, Egede LE. Impact of medical and psychiatric multi-morbidity on mortality in diabetes: emerging evidence. BMC Endocr. Disord. 2014;14(1):1.24383500
341 Maguen S, Madden E, Cohen B, . The relationship between body mass index and mental health among Iraq and Afghanistan veterans. J. Gen. Intern. Med. Jul 2013;28 Suppl 2:S563-570.23807066
342 Morden NE, Berke EM, Welsh DE, McCarthy JF, Mackenzie TA, Kilbourne AM. Quality of care for cardiometabolic disease: associations with mental disorder and rurality. Med. Care. Jan 2010;48(1):72-78.19927015
343 Morden NE, Lai Z, Goodrich DE, . Eight-year trends of cardiometabolic morbidity and mortality in patients with schizophrenia. Gen. Hosp. Psychiatry. 2012;34(4):368-379.22516216
344 Nelson LA, Graham MR, Lindsey CC, Rasu RS. Adherence to antihyperlipidemic medication and lipid control in diabetic Veterans Affairs patients with psychotic disorders. Psychosomatics. Jul-Aug 2011;52(4):310-318.21777713
345 Nelson LA, Graham MR, Lindsey CC, Rasu RS. Medication adherence and glycemic control in patients with psychotic disorders in the Veterans Affairs healthcare system. Pharm. Pract. (Granada). 2011;9(2):57-65.24688610
346 Sullivan G, Mittal D, Reaves CM, . Influence of schizophrenia diagnosis on providers' practice decisions. J. Clin. Psychiatry. 2015;76(8):1068-1074.26335084
347 Taveira TH, Pirraglia PA, Cohen LB, Wu WC. Efficacy of a pharmacist-led cardiovascular risk reduction clinic for diabetic patients with and without mental health conditions. Prev. Cardiol. Fall 2008;11(4):195-200.19476571
348 Trief PM, Ouimette P, Wade M, Shanahan P, Weinstock RS. Post-traumatic stress disorder and diabetes: co-morbidity and outcomes in a male veterans sample. J. Behav. Med. Oct 2006;29(5):411-418.16865552
349 Weitlauf J, Jones S, Xu X, . Receipt of Cervical Cancer Screening in Female Veterans: Impact of Posttraumatic Stress Disorder and Depression. Womens Health Issues. May-Jun 2013;23(3):e153-159.23660429
350 Yee EF, White R, Lee SJ, . Mental illness: is there an association with cancer screening among women veterans? Womens Health Issues. Jul-Aug 2011;21(4 Suppl):S195-202.21724141
351 Chumbler NR, Jia H, Phipps MS, . Does inpatient quality of care differ by age among US veterans with ischemic stroke? J. Stroke Cerebrovasc. Dis. Nov 2012;21(8):844-851.21641817
352 Chumbler NR, Jia H, Phipps MS, . Postdischarge quality of care: do age disparities exist among Department of Veterans Affairs ischemic stroke patients? J. Rehabil. Res. Dev. 2013;50(2):263-272.23761007
353 DiNapoli EA, Cully JA, Wayde E, Sansgiry S, Yu HJ, Kunik ME. Age as a predictive factor of mental health service use among adults with depression and/or anxiety disorder receiving care through the Veterans Health Administration. Int. J. Geriatr. Psychiatry. Sep 21 2015.
354 Frueh BC, Grubaugh AL, Acierno R, Elhai JD, Cain G, Magruder KM. Age differences in posttraumatic stress disorder, psychiatric disorders, and healthcare service use among veterans in Veterans Affairs primary care clinics. Am. J. Geriatr. Psychiatry. Aug 2007;15(8):660-672.17670996
355 Ho PM, Prochazka AV, Magid DJ, . The association between processes, structures and outcomes of secondary prevention care among VA ischemic heart disease patients. BMC Cardiovasc. Disord. 2006;6:6.16469100
356 Lehavot K, O'Hara R, Washington DL, Yano EM, Simpson TL. Posttraumatic stress disorder symptom severity and socioeconomic factors associated with Veterans Health Administration use among women veterans. Womens Health Issues. Sep-Oct 2015;25(5):535-541.26123641
357 Mohamed S, Rosenheck R. Pharmacotherapy for older veterans diagnosed with posttraumatic stress disorder in Veterans Administration. Am. J. Geriatr. Psychiatry. 2008;16(10):804-812.18827226
358 Partin MR, Noorbaloochi S, Grill J, . The interrelationships between and contributions of background, cognitive, and environmental factors to colorectal cancer screening adherence. Cancer Causes Control. Sep 2010;21(9):1357-1368.20419343
359 Plomondon ME, Ho PM, Wang L, . Severe mental illness and mortality of hospitalized ACS patients in the VHA. BMC Health Serv. Res. 2007;7:146.17877804
360 Pogach L. Interplay of Chronic Illness, Race, Age and Sex in Glycemic Control. HSR&D study (IIR 08-355). 2013; http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141699779. Accessed November 14, 2016.
361 van Ryn M, Phelan SM, Arora NK, . Patient-reported quality of supportive care among patients with colorectal cancer in the Veterans Affairs Health Care System. J. Clin. Oncol. 2014;32(8):809-815.24493712
362 Washington DL, Bean-Mayberry B, Riopelle D, Yano EM. Access to care for women Veterans: delayed healthcare and unmet need. J. Gen. Intern. Med. 2011;26(Suppl 2):655-661.21989618
363 Abrams TE, Vaughan-Sarrazin M, Kaboli PJ. Mortality and revascularization following admission for acute myocardial infarction: implication for rural veterans. J. Rural Health. 2010;26(4):310-317.21029165
364 Bailey BA, Manning T, Peiris AN. The impact of living in rural and urban areas: vitamin D and medical costs in veterans. J. Rural Health. 2012;28(4):356-363.23017006
365 Bouldin ED, Taylor LL, Littman AJ, Karavan M, Rice K, Reiber GE. Chronic lower limb wound outcomes among rural and urban veterans. J. Rural Health. 2015;31(4):410-420.25953330
366 Brooks E, Dailey N, Bair B, Shore J. Rural women veterans demographic report: defining VA users' health and health care access in rural areas. J. Rural Health. 2014;30(2):146-152.24689540
367 Carey K, Montez-Rath ME, Rosen AK, Christiansen CL, Loveland S, Ettner SL. Use of VA and Medicare services by dually eligible veterans with psychiatric problems. Health Serv. Res. 2008;43(4):1164-1183.18355256
368 Cully JA, Jameson JP, Phillips LL, Kunik ME, Fortney JC. Use of psychotherapy by rural and urban veterans. J. Rural Health. Summer 2010;26(3):225-233.20633090
369 Finegan MS, Gao J, Pasquale D, Campbell J. Trends and geographic variation of potentially avoidable hospitalizations in the veterans health-care system. Health Serv. Manage. Res. 2010;23(2):66-75.20424274
370 Friedman SA, Frayne SM, Berg E, . Travel time and attrition from VHA care among women veterans: how far is too far? Med. Care. 2015;53(4 Suppl 1):S15-22.25767970
371 Goldberg DS, French B, Forde KA, . Association of distance from a transplant center with access to waitlist placement, receipt of liver transplantation, and survival among US veterans. JAMA. 2014;311(12):1234-1243.24668105
372 Hudson TJ, Fortney JC, Williams JS, Austen MA, Pope SK, Hayes CJ. Effect of rural residence on use of VHA mental health care among OEF/OIF veterans. Psychiatric services (Washington, D.C.). 2014;65(12):1420-1425.
373 Lund BC, Charlton ME, Steinman MA, Kaboli PJ. Regional differences in prescribing quality among elder veterans and the impact of rural residence. J. Rural Health. 2013;29(2):172-179.23551647
374 Lynch CP, Strom JL, Egede LE. Disparities in diabetes self-management and quality of care in rural versus urban veterans. J. Diabetes Complications. 2011;25(6):387-392.21983152
375 Maciejewski ML, Perkins M, Li YF, Chapko M, Fortney JC, Liu CF. Utilization and expenditures of veterans obtaining primary care in community clinics and VA medical centers: an observational cohort study. BMC Health Serv. Res. 2007;7:56.17442115
376 McCarthy JF, Blow FC, Valenstein M, . Veterans Affairs Health System and mental health treatment retention among patients with serious mental illness: evaluating accessibility and availability barriers. Health Serv. Res. Jun 2007;42(3 Pt 1):1042-1060.17489903
377 McCarthy JF, Blow FC, Ignacio RV, Ilgen MA, Austin KL, Valenstein M. Suicide among patients in the Veterans Affairs health system: rural-urban differences in rates, risks, and methods. Am. J. Public Health. 2012;102 Suppl 1(1254074, 3xw):S111-117.22390583
378 Mohamed S, Neale M, Rosenheck RA. VA intensive mental health case management in urban and rural areas: veteran characteristics and service delivery. Psychiatr. Serv. Jul 2009;60(7):914-921.19564221
379 Nash DL, Wilkinson J, Paradis B, Kelley S, Naseem A, Grant KM. Trauma and substance use disorders in rural and urban veterans. J. Rural Health. 2011;27(2):151-158.21457307
380 Ohl M, Tate J, Duggal M, . Rural residence is associated with delayed care entry and increased mortality among veterans with human immunodeficiency virus infection. Med. Care. 2010;48(12):1064-1070.20966783
381 Ohl M, Lund B, Belperio PS, . Rural residence and adoption of a novel HIV therapy in a national, equal-access healthcare system. AIDS Behav. 2013;17(1):250-259.22205324
382 Ohl ME, Richardson K, Kaboli PJ, Perencevich EN, Vaughan-Sarrazin M. Geographic access and use of infectious diseases specialty and general primary care services by veterans with HIV infection: Implications for telehealth and shared care programs. J. Rural Health. 2014;30(4):412-421.24702698
383 Patterson BJ, Kaboli PJ, Tubbs T, Alexander B, Lund BC. Rural access to clinical pharmacy services. J. Am. Pharm. Assoc. (2003). 2014;54(5):518-525.25216881
384 Pfeiffer PN, Glass J, Austin K, Valenstein M, McCarthy JF, Zivin K. Impact of distance and facility of initial diagnosis on depression treatment. Health Serv. Res. 2011;46(3):768-786.21210800
385 Phipps MS, Jia H, Chumbler NR, . Rural-urban differences in inpatient quality of care in US Veterans with ischemic stroke. J. Rural Health. 2014;30(1):1-6.24383479
386 Ripley DCC, Kwong PL, Vogel WB, Kurichi JE, Bates BE, Davenport C. How does geographic access affect in-hospital mortality for veterans with acute ischemic stroke? Med. Care. 2015;53(6):501-509.25961660
387 Rongey C, Shen H, Hamilton N, Backus LI, Asch SM, Knight S. Impact of rural residence and health system structure on quality of liver care. PLoS One. 2013;8(12):e84826.24386420
388 Sarangarm D, Knepper J, Marek J, Biggs KL, Robertson D, Langsfeld M. Post-endovascular aneurysm repair patient outcomes and follow-up are not adversely impacted by long travel distance to tertiary vascular surgery centers. Ann. Vasc. Surg. 2010;24(8):1075-1081.21035700
389 Skolarus TA, Chan S, Shelton JB, . Quality of prostate cancer care among rural men in the Veterans Health Administration. Cancer. 2013;119(20):3629-3635.23913676
390 Thorpe JM, Van Houtven CH, Sleath BL, Thorpe CT. Rural-urban differences in preventable hospitalizations among community-dwelling veterans with dementia. J. Rural Health. 2010;26(2):146-155.20447001
391 Turner AP, Chapko MK, Yanez D, . Access to multiple sclerosis specialty care. PM R. 2013;5(12):1044-1050.23920332
392 Wallace AE, Weeks WB, Wang S, Lee AF, Kazis LE. Rural and urban disparities in health-related quality of life among veterans with psychiatric disorders. Psychiatr. Serv. Jun 2006;57(6):851-856.16754763
393 Wallace AE, MacKenzie TA, Wright SM, Weeks WB. A cross-sectional, multi-year examination of rural and urban Veterans Administration users: 2002-2006. Mil. Med. 2010;175(4):252-258.20446500
394 Wallace AE, Lee R, Mackenzie TA, . A longitudinal analysis of rural and urban veterans' health-related quality of life. J. Rural Health. 2010;26(2):156-163.20447002
395 Weeks WB, Wallace AE, Wang S, Lee A, Kazis LE. Rural-urban disparities in health-related quality of life within disease categories of Veterans. J. Rural Health. Summer 2006;22(3):204-211.16824163
396 West AN, Weeks WB, Wallace AE. Rural veterans and access to high-quality care for high-risk surgeries. Health Serv. Res. 2008;43(5 Pt 1):1737-1751.18665855
397 Whealin JM, Stotzer RL, Pietrzak RH, . Deployment-related sequelae and treatment utilization in rural and urban war veterans in Hawaii. Psychol. Serv. 2014;11(1):114-123.24099457
398 Arozullah AM. The Impact of Health Literacy on Racial Differences in Cancer Stage at Presentation. HSR&D study (IIR 02-010). 2007; http://www.hsrd.research.va.gov/research/abstracts.cfm?Project_ID=2141692578. Accessed November 14, 2016.
399 Gabrielian S, Yuan AH, Andersen RM, Rubenstein LV, Gelberg L. VA health service utilization for homeless and low-income Veterans: a spotlight on the VA Supportive Housing (VASH) program in greater Los Angeles. Med. Care. 2014;52(5):454-461.24714583
400 Knight SJ, Latini DM, Hart SL, . Education predicts quality of life among men with prostate cancer cared for in the Department of Veterans Affairs: a longitudinal quality of life analysis from CaPSURE. Cancer. 2007;109(9):1769-1776.17380491
401 Nelson K, Taylor L, Lurie N, Escarce J, McFarland L, Fihn SD. Neighborhood environment and health status and mortality among veterans. J. Gen. Intern. Med. 2011;26(8):862-867.21499826
402 Widome R, Jensen A, Fu SS. Socioeconomic disparities in sleep duration among veterans of the US wars in Iraq and Afghanistan. Am. J. Public Health. 2015;105(2):e70-74.
403 Littman AJ, Koepsell TD, Forsberg CW, Haselkorn JK, Boyko EJ. Preventive services in veterans in relation to disability. J. Rehabil. Res. Dev. 2012;49(3):339-350.22773194
404 Belsher BE, Tiet QQ, Garvert DW, Rosen CS. Compensation and treatment: disability benefits and outcomes of U.S. veterans receiving residential PTSD treatment. J. Trauma. Stress. 2012;25(5):494-502.23047625
405 Berke GM, Fergason J, Milani JR, . Comparison of satisfaction with current prosthetic care in veterans and servicemembers from Vietnam and OIF/OEF conflicts with major traumatic limb loss. J. Rehabil. Res. Dev. 2010;47(4):361-371.20803404
406 Hermes EDA, Rosenheck RA, Desai R, Fontana AF. Recent trends in the treatment of posttraumatic stress disorder and other mental disorders in the VHA. Psychiatric services (Washington, D.C.). 2012;63(5):471-476.
407 Jain S, Greenbaum MA, Rosen CS. Do. Veterans With Posttraumatic Stress Disorder Receive First-Line Pharmacotherapy? Results From the Longitudinal Veterans Health Survey. Primary Care Companion for CNS Disorders. 2012;14(2):7.
408 Mohanty AF, Muthukutty A, Carter ME, . Chronic multisymptom illness among female Veterans deployed to Iraq and Afghanistan. Med. Care. 2015;53(4 Suppl 1):S143-148.25767968
409 Paddock SM, Woodroffe A, Watkins KE, . The quality of mental health care for veterans of Operation Enduring Freedom/Operation Iraqi Freedom. Med. Care. 2013;51(1):84-89.23032356
410 Washington DL, Bean-Mayberry B, Hamilton AB, Cordasco KM, Yano EM. Women veterans' healthcare delivery preferences and use by military service era: findings from the National Survey of Women Veterans. J. Gen. Intern. Med. 2013;28 Suppl 2:S571-576.23807067
411 Washington DL, Bird CE, LaMonte MJ, . Military Generation and Its Relationship to Mortality in Women Veterans in the Women's Health Initiative. Gerontologist. Feb 2016;56 Suppl 1:S126-137.26768386
412 Alessi E, Meyer I, Martin J. PTSD and sexual orientation: an examination of criterion A1 and non-criterion A1 events. Psychol. Trauma. 2013;5(2):149-157.26113955
413 Blosnich J, Bossarte R, Silver E, Silenzio V. Health care utilization and health indicators among a national sample of U.S. veterans in same-sex partnerships. Mil. Med. 2013;178(2):207-212.23495467
414 Blosnich J, Foynes MM, Shipherd JC. Health disparities among sexual minority women veterans. Journal of women's health (2002). 2013;22(7):631-636.
415 Blosnich JR, Mays VM, Cochran SD. Suicidality Among Veterans: Implications of Sexual Minority Status. Am. J. Public Health. Sep 2014;104(Suppl 4):S535-537.25100418
416 Lehavot K, Browne KC, Simpson TL. Examining sexual orientation disparities in alcohol misuse among women veterans. Am. J. Prev. Med. 2014;47(5):554-562.25241197
417 Lehavot K, Simpson TL. Trauma, posttraumatic stress disorder, and depression among sexual minority and heterosexual women veterans. J. Couns. Psychol. 2014;61(3):392-403.25019543
418 Mattocks KM, Sadler A, Yano EM, . Sexual victimization, health status, and VA healthcare utilization among lesbian and bisexual OEF/OIF veterans. J. Gen. Intern. Med. Jul 2013;28 Suppl 2:S604-608.23807072
419 O'Toole TP, Bourgault C, Johnson EE, . New to care: demands on a health system when homeless veterans are enrolled in a medical home model. Am. J. Public Health. 2013;103 Suppl 2(1254074, 3xw):S374-379.24148042
420 Tsai J, Doran KM, Rosenheck RA. When health insurance is not a factor: national comparison of homeless and nonhomeless US veterans who use Veterans Affairs Emergency Departments. Am. J. Public Health. 2013;103 Suppl 2(1254074, 3xw):S225-231.24148061
421 O'Toole TP, Pirraglia PA, Dosa D, . Building care systems to improve access for high-risk and vulnerable veteran populations. J. Gen. Intern. Med. 2011;26 Suppl 2(8605834):683-688.
422 Zillich AJ, Shay K, Hyduke B, . Quality improvement toward decreasing high-risk medications for older veteran outpatients. J. Am. Geriatr. Soc. 2008;56(7):1299-1305.18537846
423 Belote J, Fulton LV, Brooks MS. Patient satisfaction as a function of in-house versus contract staffing models in Veterans Affairs community-based outpatient clinics. Mil. Med. 2012;177(1):23-26.22338974
424 Malhotra A, Vaughan-Sarrazin M, Charlton ME, Rosenthal GE. Comparison of colorectal cancer screening in veterans based on the location of primary care clinic. J. Prim. Care Community Health. 2014;5(1):24-29.24327586
425 Nelson RE, Hicken B, West A, Rupper R. The effect of increased travel reimbursement rates on health care utilization in the VA. J. Rural Health. 2012;28(2):192-201.22458320
426 Nelson RE, Hicken B, Cai B, Dahal A, West A, Rupper R. Utilization of travel reimbursement in the Veterans Health Administration. J. Rural Health. 2014;30(2):128-138.24689538
427 Seal KH, Cohen G, Bertenthal D, Cohen BE, Maguen S, Daley A. Reducing barriers to mental health and social services for Iraq and Afghanistan veterans: Outcomes of an integrated primary care clinic. J. Gen. Intern. Med. 2011;26(10):1160-1167.21647750
428 McGuire J, Gelberg L, Blue-Howells J, Rosenheck RA. Access to primary care for homeless veterans with serious mental illness or substance abuse: a follow-up evaluation of co-located primary care and homeless social services. Adm. Policy Ment. Health. 2009;36(4):255-264.19280333
429 Chrystal JG, Glover DL, Young AS, . Experience of primary care among homeless individuals with mental health conditions. PLoS One. 2015;10(2):e0117395.25659142
430 Kertesz SG, Holt CL, Steward JL, . Comparing homeless persons' care experiences in tailored versus nontailored primary care programs. Am. J. Public Health. 2013;103 Suppl 2(1254074, 3xw):S331-339.24148052
431 O'Connell MJ, Kasprow W, Rosenheck R. Direct placement versus multistage models of supported housing in a population of veterans who are homeless. Psychol. Serv. 2009;6(3):190-201.
432 O'Toole TP, Buckel L, Bourgault C, . Applying the chronic care model to homeless veterans of a population approach to primary care on utilization and clinical outcomes. Am. J. Public Health. 2010;100(12):2493-2499.20966377
433 Kilbourne AM, Lai Z, Bowersox N, Pirraglia P, Bauer MS. Does colocated care improve access to cardiometabolic screening for patients with serious mental illness? Gen. Hosp. Psychiatry. 2011;33(6):634-636.21872334
434 Kilbourne AM, Pirraglia PA, Lai Z, . Quality of general medical care among patients with serious mental illness: does colocation of services matter? Psychiatric services (Washington, D.C.). 2011;62(8):922-928.
435 Pirraglia PA, Kilbourne AM, Lai Z, Friedmann PD, O'Toole TP. Colocated general medical care and preventable hospital admissions for veterans with serious mental illness. Psychiatric services (Washington, D.C.). 2011;62(5):554-557.
436 Pomerantz A, Cole BH, Watts BV, Weeks WB. Improving efficiency and access to mental health care: combining integrated care and advanced access. Gen. Hosp. Psychiatry. 2008;30(6):546-551.19061681
437 Szymanski BR, Bohnert KM, Zivin K, McCarthy JF. Integrated care: treatment initiation following positive depression screens. J. Gen. Intern. Med. 2013;28(3):346-352.23150068
438 Fortney JC, Pyne JM, Kimbrell TA, . Telemedicine-based collaborative care for posttraumatic stress disorder: a randomized clinical trial. JAMA Psychiatry. 2015;72(1):58-67.25409287
439 Mohamed S. Adaptation of intensive mental health intensive case management to rural communities in the Veterans Health Administration. Psychiatr. Q. 2013;84(1):103-114.22729625
440 Morland LA, Greene CJ, Rosen CS, . Telemedicine for anger management therapy in a rural population of combat veterans with posttraumatic stress disorder: a randomized noninferiority trial. J. Clin. Psychiatry. 2010;71(7):855-863.20122374
441 Morland LA, Mackintosh MA, Greene CJ, . Cognitive processing therapy for posttraumatic stress disorder delivered to rural veterans via telemental health: a randomized noninferiority clinical trial. J. Clin. Psychiatry. 2014;75(5):470-476.24922484
442 Turner TH, Horner MD, Vankirk KK, Myrick H, Tuerk PW. A pilot trial of neuropsychological evaluations conducted via telemedicine in the Veterans Health Administration. Telemed J. E Health. 2012;18(9):662-667.23050802
443 Bastian LA, Trentalange M, Murphy TE, . Association between women veterans' experiences with VA outpatient health care and designation as a women's health provider in primary care clinics. Womens Health Issues. 2014;24(6):605-612.25442706
444 Gray KE, Katon JG, Callegari LS, Cordasco KM, Zephyrin LC. Gynecologists in the VA: do they enhance availability of sex-specific services and policies in the emergency department? Med. Care. 2015;53(4 Suppl 1):S76-80.25767980
445 Sambamoorthi U, Bean-Mayberry B, Findley PA, Yano EM, Banerjea R. Organization of care and diagnosed depression among women veterans. Am. J. Manag. Care. 2010;16(9):657-665.20873953
446 Washington DL, Bean-Mayberry B, Mitchell MN, Riopelle D, Yano EM. Tailoring VA primary care to women veterans: association with patient-rated quality and satisfaction. Womens Health Issues. 2011;21(4 Suppl):S112-119.21724130