# METHODS

## TOPIC DEVELOPMENT

This topic was submitted to the VA ESP Coordinating Center for development by Uchenna Uchendu, MD, Director of the VHA Office of Health Equity. The research questions for this evidence map were developed after a topic refinement process that included a preliminary review of published peer-reviewed literature, and consultation with internal partners, investigators, and stakeholders. The key questions for the map are as follows:

Key Question 1. For what Veteran groups/populations are health and healthcare disparities prevalent?

Key Question 2. What are the effects of interventions implemented within the VHA to reduce health disparities?

Key Question 3. What are the research projects designed to identify or mitigate health disparities currently being funded by the VA Office of Research and Development (ORD)?

Our approach was guided by an analytic framework developed for a 2007 systematic review by Saha et al, which examined racial and ethnic disparities in the VHA. We expanded the analytic framework to include additional Veteran populations for whom a disparity may exist (see Figure 1).^3^ In the framework, first-generation studies are those that examine the prevalence of disparities in the utilization, quality of care, and health of Veterans. These studies are used to inform Key Question 1, and are included in Key Question 3. Second-generation studies examine mediating factors that may contribute to disparities for any given group/population (eg, perceived discrimination), and are included only in our search for currently funded research (Key Question 3). Third-generation studies examine interventions designed to reduce disparities. These studies are used to address Key Question 2, and are included in Key Question 3. Some studies may fall into more than one generational category. In these cases, only the data relevant to the key questions in this report were extracted.

Figure 1 Analytic Framework: Prevalence of and Interventions to Reduce Disparities in Veterans

Abbreviations: gen. = generation; KQ = Key Question; LGBT = lesbian, gay, bisexual, transgender; VAMC = Veteran Affairs Medical Center.

## SEARCH STRATEGY

We conducted a primary review of the literature by systematically searching, reviewing, and analyzing the scientific evidence as it pertained to the Key Questions in the report. In order to capture the breadth of disparities related to the utilization or quality of Veteran health or healthcare, we expanded the search strategy developed by Saha et al^30^ to include additional vulnerable Veteran populations. The search strategy was peer reviewed by a second research librarian using the instrument for Peer Review of Search Strategies (PRESS).^31,32^ For Key Questions 1 and 2, we searched the following databases for relevant literature published from 2006 through February 2016: MEDLINE, PubMed, PsycINFO, CINAHL, the Cochrane Library, Social Services Abstracts, Sociological Abstracts, and the VA's Health Services Research and Development (HSR&D) database (see Appendix A). To identify ongoing and recently completed VA research projects for Key Question 3, we searched the VA's HSR&D database for relevant studies completed or expected to be completed in 2015 or later.

We also evaluated the excluded studies and supplementary materials for Peterson et al's (2015) VA ESP evidence brief,^5^ and the bibliographies of included primary studies and relevant systematic and non-systematic reviews, including Gierisch et al's (2014)^17^ VA ESP review on disparities on the quality of care for patients with mental illness, Spoont et al's (2011)^20^ VA ESP review examining ambulatory care in rural versus urban populations, Bean-Mayberry et al's (2010)^10^ VA ESP review examining women's health in the VA, and Kehle et al's (2011)^21^ ESP review examining interventions to improve Veterans' access to care. To identify published and unpublished studies for all Key Questions, we searched ClinicalTrials.gov and the VA HSR&D and ESP websites, and contacted the directors of several VA research offices known to emphasize health disparity research (Appendix A).

## STUDY SELECTION

Criteria for population, interventions, comparators, outcomes, timing, and setting (PICOTS) were developed in collaboration with Dr. Uchendu and a Technical Expert Panel (TEP; listed in Appendix B), and are provided in Table 1. Using pre-specified inclusion criteria (Appendix C), 2 independent reviewers evaluated titles and abstracts for a random 10% of the search yield in order to ensure reliability between reviewers, with the remaining 90% decided by a single reviewer. We reviewed funded research for inclusion according to the same pre-specified inclusion criteria. At the full-text screening stage, 2 independent reviewers assessed all articles for inclusion, and discordant results were resolved through consensus or consultation with a third reviewer.

Table 1 PICOTS by Key Question

Key Questions (KQs) | KQ1. For what Veteran groups/populations are health and healthcare disparities prevalent? | KQ2. What are the effects of interventions implemented within the VHA to reduce health disparities? | KQ3. What are the research projects designed to identify or mitigate health disparities currently being funded by the VA Office of Research and Development (ORD)?
Population | Veterans only
Interventions | NA | Any interventions designed specifically or are being specifically used to reduce disparities, or examine mediators associated with health disparities for Veterans.
Comparators | - Control group within the same group; - Comparison to other groups relevant to the population
Outcomes | - Utilization of healthcare services; - Quality of healthcare services; 1. Intermediate/process of care measures; 2. Patient evaluations of care; - Patient health outcomes | - Utilization of healthcare services; - Quality of healthcare services; 1. Intermediate/process of care measures; 2. Patient evaluations of care; - Patient health outcomes; - Mediators; 1. System level (eg, distribution of services); 2. Provider level (eg, racial bias); 3. Patient level (eg, trust); 4. Provider-patient level (eg, communication)
Timing | No restrictions
Study design | Original research, systematic review, or meta-analysis
Setting | VHA or community settings

We included only studies of Veteran populations examining health disparities. For all Key Questions, we included studies with a comparison group within the same population or another relevant group, as well as studies providing a pre-post intervention comparison. We included studies examining outcomes related to the utilization, the quality of healthcare, or patient health outcomes. We included all study designs except for systematic or nonsystematic reviews, which were manually searched for eligible studies.

## DATA ABSTRACTION

Data from studies meeting inclusion criteria were abstracted by one investigator and confirmed by a second. From each study, we abstracted data related to study design, setting, population, number of subjects, clinical topic, groups compared, outcomes, type of intervention (when applicable), whether a mediator was examined (and type), and a summary of findings for each outcome type.

## QUALITY ASSESSMENT

Given that the purpose of our review was to identify and classify the body of research related to health disparities affecting Veterans, we did not formally assess the quality of individual studies. For Key Question 1, we instead calculated a rough estimate of confidence for each study based on study design, whether the study controlled or adjusted for confounding variables, number of sites, and sample size. Table 2 outlines the criteria we used for scoring. For Key Question 2, we simply note the study design and sample size.

Table 2 Description of confidence scores used for Key Question 1

Category; Points | Description
Study Design 0 to 1 | 1 point for prospective studies. 0 points for all other designs.
Controlled for Confounders -1 to 0 | -1 point if the study did not control for confounding variables. 0 points for all others.
Study Site(s) 0 to 1 | 1 point for multi-site studies and data from national samples. 0 points for single-site study.
Sample Size 0 to 2 | Key Question 1: 2 points for studies with samples ≥100,000. 1 point for studies with samples ≥10,000. 0 points for studies <10,000.

## DATA SUMMARY

Our search for vulnerable populations was intentionally broad, to capture the breadth of disparities related to health or healthcare affecting Veterans. We mapped original research by abstracting relevant data for each Key Question and disparity population: race or ethnicity; women; mental health; age; rural residence; distance from a Veterans Affairs Medical Center (VAMC) or treatment facility (including studies examining Community Based Outpatient Clinics [CBOCs]); socioeconomic status (SES); homelessness; era of military service; lesbian, gay, bisexual, or transgender (LGBT) identity; and disability. We purposefully separated studies examining rural populations from those examining distance from a VAMC. Although challenges related to lack of access due to distance are likely applicable to Veterans living in rural areas, we suspect that the health and healthcare of rural Veterans may also be influenced by additional cultural factors specific to living in rural areas.

We categorized studies for each population into those examining the following outcome categories:

1. utilization (eg, inpatient, outpatient, specialty care visits),
2. the quality of care (eg, processes of care [such as blood pressure screening], patient evaluations of care, intermediate outcomes [such as blood pressure control]),
3. patient health outcomes (eg, mortality)

For each category, we recorded whether a study found a disparity, no disparity, or whether the findings within an outcome category were mixed or unclear. If a study reported multiple outcomes within the same category (eg, blood pressure screening and control), we classified a study as mixed if the findings were not in agreement (eg, found significantly fewer screenings, but no difference in blood pressure control).

We classified a finding as a disparity if it conflicted with the clinically appropriate or expected outcome for each vulnerable population. For example, a study that found higher mortality rates in Veterans of color, compared to White Veterans, would be classified as a disparity. However, for studies examining age-related or era of military service-related disparities, we did not consider higher mortality rates in older adults and/or earlier eras of service (eg, WWII or Vietnam) to be a disparity in health, for we would expect higher mortality rates in older populations. For outcomes related to outpatient utilization, we classified lower utilization as a disparity for populations for which we know access is a primary issue (eg, distance from a VA Medical Center or rural residence). However, for studies examining other types of disparities, if the rate at which the study population should be utilizing outpatient care was unclear, we classified significantly higher or lower rates of utilization as mixed or unclear, as we could not determine if those rates reflected better or poorer Veteran health, or if they represented a disparity related to access or other factors. For age-related disparities, if a study found either older or younger adults to be at a disadvantage that was not clinically normative, we classified it as a disparity.

For studies examining interventions designed to reduce disparities (Key Question 2), we categorized interventions into 1) patient-focused interventions, 2) provider-focused interventions, 3) technology interventions, and 4) system-level interventions. For each study we recorded whether the study findings were positive/no difference between the intervention and usual care (eg, non-inferiority studies), not positive/equivalent, or if findings were mixed or unclear. Similar to studies examining prevalence, if a study examining multiple outcomes reported both positive and negative findings, we classified the study as mixed or unclear. Also similar to Key Question 1, utilization outcomes were classified as mixed or unclear if the rate at which a population should be utilizing care was unclear. By default, we classified studies examining Community Based Outpatient Clinics (CBOCs) as examining distance from a VAMC, unless the article included a measure of ruality or specifically described the study population as living in a rural area.

## RATING THE BODY OF EVIDENCE

The purpose of our report was to describe the state of health disparities affecting Veterans by identifying and classifying current research. Thus, we did not formally assess the overall body of evidence. For Key Question 1, in lieu of a rating of the overall strength of evidence, for each outcome category (ie, utilization, the quality of care, patient health outcomes) within each vulnerable population, we provide a mean estimate of confidence for all studies reporting a) a disparity, b) no disparity, or c) that we determined were mixed or unclear (see Table 2 for a description of confidence scores for Key Question 1). We provide no estimates of confidence for Key Questions 2 or 3.

## PEER REVIEW

A draft version of this report was reviewed by 4 individuals with technical expertise and clinical leadership. Their comments and our responses are presented in Appendix B.