# INTRODUCTION

Today's Veteran population is racially and ethnically diverse, and includes more women and individuals from vulnerable populations, such as those identifying as lesbian, gay, bisexual, and transgender (LGBT), than at any other time in history. While the equal access nature of the Veterans Health Administration (VHA) may succeed in mitigating some of the disparities related to socioeconomic status (SES), it does not directly address the potential for disparities related sociodemographic factors (eg, race/ethnicity, gender, LGBT identity, age), geographic location, and mental health status. An understanding of whether disparities in utilization, health, or healthcare exists for Veterans belonging to vulnerable populations is vital. Both the Veterans Administration (VA) and the VHA have emphasized the mitigation and elimination of health disparities in their strategic plans, and have outlined specific goals in the VHA Health Equity Plan and the Blueprint for Excellence.^1,2^ Over the last decade, the VA Evidence-based Synthesis Program (ESP) and other organizations have published systematic reviews examining the quality of the health and healthcare experienced by a variety of vulnerable Veteran populations.

## RACE AND ETHNICITY

Three VA ESP reviews have examined the topic of racial and ethnic disparities. A comprehensive review by Saha et al (2007) examined racial and ethnic disparities within the VHA, factors contributing to disparities, interventions designed to mitigate disparities, and ongoing research funded by the VA Health Services Research and Development (HSR&D).^3^ Findings included no clear pattern of disparities by clinical area; however, disparities were more prevalent for processes requiring a higher degree of decision making, communication, or effort; process of care outcomes such as blood pressure, glucose, and cholesterol favored White Veterans; and disparities affected African American/Black and Hispanic/Latino Veterans most significantly.^3^ In 2011, Quinones and others focused on interventions to reduce racial and ethnic disparities both inside and out of the VHA, and identified 5 studies examining Veterans of color (African American/Black, Hispanic/Latino, American Indian/Alaksa Native).^4^ Most recently, Peterson et al (2015) published a limited evidence brief updating Saha et al's review. The evidence brief included only a synthesis of morbidity and mortality outcomes, and was accompanied by supplementary data tables describing additional outcomes such as access to care, screening, and other process of care and patient outcomes.^5^ Findings included higher morbidity/mortality rates for African American/Black Veterans (as compared to Whites) associated with a wide range of conditions (eg, colon cancer, chronic kidney disease [CKD], Human Immunodeficiency Virus [HIV], diabetes, posttraumatic stress disorder [PTSD], venous thromboembolism), and for Hispanic/Latino Veterans with hepatitis C.^5^

## WOMEN'S HEALTH

Women are currently the fastest-growing cohort within the Veteran community, and by 2040 will make up 16% of the Veteran population.^6^ A recent study of Operation Enduring Freedom (OEF) and Operation Iraqi Freedom (OIF) Veterans receiving care through the VHA found that women were more likely than men to have back, musculoskeletal, and joint problems in the year after returning from deployment, with the odds increasing up to 7 years post-deployment.^7^ A 2014 study examining trends in gender disparities associated with gender-neutral VHA clinical measures from 2008-2014 found that gender differences in screening for depression and PTSD were eliminated over the study period, and there were significant reductions in disparities related to hypertension and diabetes control, although disparities remained in other areas. For example, in 2012, female Veterans with a history of diabetes or ischemic heart disease had higher average low-density lipoprotein (LDL) levels and lower rates of appropriate statin prescriptions than their male counterparts (79.5% of female Veterans versus 88.9% of males), increasing their risk for future cardiovascular events.^8^

In 2006, an ESP review by Goldzweig et al assessed the body of VA research related to women's health. The review identified 182 studies published from 1978 to 2004, which were largely observational and descriptive in nature, with only 2 randomized controlled trials (RCTs).^9^ An update examining research published between 2004 and 2008 was published in 2010. Findings were consistent with increasing attention to issues related to disparities in care for women Veterans, with 195 articles identified, of which 5 were RCTs.^10^ Since 2008, the VA and VHA have made a significant effort to increase awareness of women's health and reduce disparities. In 2008, the VA launched a Women's Health improvement initiative, including a 5-year plan to reduce disparities, and in 2011 Women's Health became part of the Office of Patient Care Services (PCS), allowing for better integration of services and coordination of care.^11,12^ In addition, women Veteran's heath has increasingly become a research priority in the VA. An update to the 2010 ESP review on women's health was recently published.^13,14^

## MENTAL HEALTH

Veterans experience a high burden of mental health conditions. According to a recent analysis of VHA utilization by OEF, OIF, and Operation New Dawn (OND) Veterans, 57.6% of Veterans receiving care through the VHA were diagnosed with a mental health condition, with more than half diagnosed with PTSD.^15^ In addition, individuals with mental health conditions experience a disproportionately high rate of co-occurring medical conditions, such as diabetes and pulmonary and cardiovascular disease.^16^ A 2014 ESP review examined disparities in the receipt of preventive care, or the management of chronic conditions among Veterans and non-Veteran adults with mental health disorders.^17^ Findings related to mammography, pap smears, and colorectal cancer screening within the VHA were inconsistent, with Veterans with a mental health condition less likely to receive a pneumococcal vaccine, and those with diabetes less likely to receive eye and foot exams. However, Veterans with a mental health condition and comorbid diabetes were more likely to receive HbA1c monitoring, and Veterans with PTSD and depressive disorders were more likely to be both screened for tobacco use and referred to smoking cessation counseling.^17^

## RURAL RESIDENCE AND DISTANCE

Roughly 3 million Veterans – one-third of all Veterans served by the VHA – live in rural areas.^18^ 2 reviews have focused specifically on the health of rural Veterans. In 2008, the VA National Center for Patient Safety published a review examining the status of rural Veterans' health, associated characteristics of care, and variables related to disparities, such as access, utilization patterns, rural care delivery models, and healthcare settings used by Veterans.^19^ More recently, an ESP review examined urban versus rural ambulatory care in VHA and non-VHA settings.^20^ The review focused on differences in healthcare access and utilization between rural and urban patients, as well as differences in process of care and patient outcomes. Findings indicated lower cancer screening rates (eg, breast, cervical) and higher suicide rates associated with differential use of antidepressants in patients living in rural areas, and that despite better continuity of care with a specific primary care provider (PCP), patients living in rural areas were more likely to have a physician extender as their PCP, and have poorer access to specialty care, including mental health providers. A second ESP review examined interventions to improve access to care, and addressed issues related to both rural residence and distance from a VA medical center. The review concluded that there was a fair amount of evidence that interventions to improve access were effective at improving outcomes such as utilization and patient satisfaction, but that more research was needed examining the quality of care and patient health.^21^

## LESBIAN, GAY, BISEXUAL, AND TRANSGENDER (LGBT)

Recent estimates indicate that roughly 2.2% of military personnel in the United States identify as lesbian, gay, or bisexual (LGB),^22^ with data based on the 2000 Census estimating nearly one million LGB Veterans.^23^ In addition, estimates based on the 2011 American Community Survey (ACS) suggest that there are more than 130,000 transgender Veterans.^24^ Studies examining health disparites experienced by LGBT Veterans are limited, and to our knowledge, no systematic reviews have been published to date. The limited research that exists indicates that transgender Veterans are more likely to be diagnosed with nearly all psychological and physical health conditions.^25^ In addition, across all care providers, LGB Veterans are less likely to seek medical care, are more likely to be HIV+, and are more likely to have activity limitations due to physical, mental, or emotional problems.^26^ In addition, studies have also found that LGBT Veterans may fear mistreatment related to their LGBT identity,^27^ that sexual orientation is often not assessed by providers at the VHA,^28^ and that when surveyed, many VHA providers believed it was inappropriate to discuss sexual orientation in a clinical setting and/or felt uncomfortable doing so.^29^

## THE CURRENT REVIEW

Despite the VHA's commitment to reducing disparities, the rate at which health and healthcare disparities affect Veterans remains unclear. In order to guide future research and policy decisions for the VA, the VA Office of Heath Equity (OHE) partnered with the VA ESP to examine the state of research on health disparities affecting vulnerable Veterans. Previous VA ESP and other VA-funded programs have examined disparities related to race/ethnicity, rural residence, distance, mental health, and women. However, disparities, or the potential for disparities in utilization, health, or healthcare may also affect other Veteran populations, such as older or younger Veterans, LGBT Veterans, and Veterans of low SES, as well as those with a physical or cognitive disability, or other characteristics. The purpose of this report was to identify studies, 1) examining the prevalence of disparities in the utilization, the quality of healthcare, or the health of Veterans, 2) evaluating the interventions designed to mitigate disparities within the VHA, and 3) examining health disparities funded through the VA Office of Research and Development that are currently ongoing or were recently closed. To characterize the original research relevant to disparities in Veterans and the interventions designed and implemented within the VHA to address them, we provide high level evidence maps. Our findings will inform stakeholders of the areas in which disparities may be present, and will also highlight the populations for which more research is needed to better understand and address the need for equitable healthcare for all Veterans.