# DISCUSSION AND CONCLUSION

Our review of the evidence examining health disparities experienced by Veterans yielded 464 studies, with 135 studies examining multiple populations, and many reporting multiple outcomes. For Key Question 1, of the 362 identified, studies examining the prevalence of disparities related to race and ethnicity were the most common, with the vast majority examining African American/Blacks, and Hispanic/Latinos a very distant second. Due to the vast differences between racial and ethnic minorities, we did not include studies which classified all Veterans of color as non-White (see Appendix T).

Many of the studies examining racial and ethnic minorities found no clear evidence of disparities. However, there were stark differences by racial/ethnic group and type of outcome. The bulk of studies examining racial/ethnic groups that comprise smaller percentages of the overall Veteran population (eg, Native Hawaiian, Pacific Islander, Asian) reported no disparities. It is important to note that the lack of significant findings in these smaller racial and ethnic groups may stem from a lack of statistical power due to their relatively small numbers, rather than an absence of disparities. Given that such a large proportion of the evidence base examining racial/ethnic disparities focuses on African American/Black Veterans, future research is needed to better understand the rapidly growing Hispanic/Latino and Asian populations, and targeted research is needed to capture the unique characteristics of American Indians/Alaska Natives, Native Hawaiians, and Pacific Islanders.

Also highly represented in the body of research were studies examining the prevalence of disparities by gender, mental health status, and age. Our evidence maps very clearly illustrate the difference in emphasis placed on certain Veteran populations, and highlight the gaps in research – in particular the limited number of studies examining disparities by socioeconomic status, and the lack of studies examining LGBT Veterans. The lack of published research examining the prevalence of disparities in LGBT Veterans was not surprising, given that compared to other vulnerable groups, the LGBT Veteran population is relatively small. In addition, our search spanned 2006 to 2016, and the Don't Ask Don't Tell Repeal Act did not take effect until late 2011.

Maps examining utilization clearly illustrate that for some populations (ie, race/ethnicity, mental health, women) utilization of care may not be an area of concern; however, it is extremely salient for other Veteran groups – in particular those living farther from VA medical centers, those living in rural areas, and homeless Veterans. In addition, studies provide some evidence that disparities in the quality of care may exist, particularly those related to age, but also in women, Veterans of color, and Veterans with mental health conditions. Finally, maps of studies examining disparities in patient health highlight a distribution of findings that lean towards no disparity or mixed/unclear findings, with the exception of those examining Veterans with mental health conditions and those of low socioeconomic status, for whom poorer health outcomes were more commonly found.

For Key Question 2, interventions most often addressed disparities related to rural residence or distance from a VA medical center, homelessness/socioeconomic status, and mental health. System-level and technology interventions were the most common, and there were just a handful of interventions aimed at providers. Missing completely were studies designed to address disparities related to LGBT identity, and studies were sparse in other areas, such as interventions to address racial and ethnic, sex, and disability-associated disparities. Our intervention map clearly illustrates that studies have reported findings that were either positive or equivalent, or mixed or unclear. However, the many blank or near-empty cells illustrate that the opportunities for further work in this area are many. When examined alongside the 40 identified current or recent VA Office of Research and Development funded health disparity studies (KQ3), we see clear gaps in research related to not only to LGBT identity, but also cognitive and physical disabilities, era of military service, and age.

The task of finding and classifying the body of research related to heath disparities affecting Veterans was a challenge, due not only to the breadth of the body of literature, but also the complexity of the topic. Despite casting a wide net for published studies and searching multiple sources for unpublished studies, we are certain that our maps do not contain every published and unpublished study examining disparities in Veterans conducted in the last 10 years. Furthermore, it is important to note that the reported findings our maps illustrate may be skewed as a result of publication bias.

To enable the capture of the presence or absence of disparities experienced by Veterans receiving care outside of the VHA (eg, Patient Centered Community Care, Veterans Choice Program, Medicare or Medicaid eligibility), we included all studies examining health disparities affecting Veterans and meeting other inclusion criteria, regardless of site of care. We did not stratify or analyze studies by site of care; thus, our report does not address the question of whether disparities in health and healthcare differ in vulnerable populations of Veterans receiving care within the VHA, in the private sector, or a combination. Given that large numbers of Veterans receive care in the community instead of or in addition to VHA care, research is needed to better understand the role of site of care in the prevalence of health disparities experienced by vulnerable Veteran populations.

While a handful of studies reported outcome data related to intersecting identities (ie, belonging to multiple vulnerable populations, for example LGBT Veterans of color) the vast majority of studies did not. Although relevant data were mapped for each of the vulnerable populations of interest reported in included studies, our maps do not fully capture those Veterans who may be at increased risk as a result of belonging to multiple vulnerable populations. Future systematic reviews targeting specific populations should include a thorough subgroup examination.

We classified studies broadly by clinical area to provide an overview of the distribution by outcomes examined (ie, utilization, quality of care, patient health outcomes) in Veteran disparity research. Due to time limitations, we were not able to examine the distribution of clinical areas by population, nor did we conduct any analysis further parsing these categories by specific condition (eg, specific types of cancer). In addition to examining vulnerable subgroups, future population specific systematic reviews should also include an analysis of the prevalence of disparities by clinical area or condition.

The vast number of studies and comparisons we examined precluded a formal evaluation of study quality and depth of knowledge. The rough confidence estimates were not intended to replace evaluations of study quality, nor was the intent to provide a standard metric with which to compare study quality between populations. Instead, the purpose of these scores was to allow us to visually represent the relative differences for each population. Furthermore, given that we did not evaluate many important study-level factors that may influence conclusions related to the presence or absence of a disparity across studies (eg, appropriateness of confounders, adjustments, and outcomes, sampling bias), the maps presented in this report should not serve as evidence upon which policy decisions affecting the health or healthcare of Veterans are formed. Instead, they should serve as a starting point – and provide the “lay of the land.” The maps in this report inform areas in which more primary research is needed – for example, the limited number of prevalence studies examining disparities by SES highlight a need for additional research to determine whether the health disparities associated with low SES in the general US population are also experienced by Veterans receiving care in VHA settings. In addition, prevalence studies are needed to better understand the disparities faced by our American Indian/Alaska Native, Asian, Pacific Islander, Native Hawaiian, and LGBT Veterans, followed by intervention studies to address the findings. The maps also serve to inform us of the areas and populations for which the research is rich, and for which a traditional systematic review would enable a deeper understanding not only of what disparities exist, but also the context and mechanisms through which they occur. Finally, they allow us to see the VHA's strengths and achievements, which in turn may serve to provide motivation to continue to work towards the goal of health equity for all Veterans.