# APPENDIX T STUDIES CLASSIFYING RACIAL/ETHNIC MINORITIES AS NON-WHITE

1 Bullock KC, Edwards KL, Greene RS, Shah SR, Blaszczyk AT. Race as a factor for intensification of diabetes medications. Diabetes Educ. 2013; 39(3):335-343.23475185
2 Burnett-Zeigler I, Zivin K, Ilgen MA, Islam K, Bohnert ASB. Perceptions of quality of health care among Veterans with psychiatric disorders. Psychiatr Serv. 2011; 62(9):1054-1059.21885584
3 Cheng EM, Siderowf AD, Swarztrauber K, Disparities of care in Veterans with Parkinson's disease. Parkinsonism Relat Disord. 2008;14(1):8-14.17702625
4 Davis TD, Deen TL, Fortney JC, Sullivan G, Hudson TJ. Utilization of VA mental health and primary care services among Iraq and Afghanistan Veterans with depression: the influence of gender and ethnicity status. Mil Med. 2014; 179(5):515-520.24806496
5 Duggal M, Goulet JL, Womack J, Comparison of outpatient health care utilization among returning women and men Veterans from Afghanistan and Iraq. BMC Health Serv Res. 2010;10:175.20565985
6 Fasoli DR, Glickman ME, Eisen SV. Predisposing characteristics, enabling resources and need as predictors of utilization and clinical outcomes for Veterans receiving mental health services. Med Care. 2010; 48(4):288-295.20355260
7 Partin MR, Noorbaloochi S, Grill J, The interrelationships between and contributions of background, cognitive, and environmental factors to colorectal cancer screening adherence. Cancer Causes Control. 2010; 21(9):1357-1368.20419343
8 Runnals JJ, Van Voorhees E, Robbins AT, Self-reported pain complaints among Afghanistan/Iraq era men and women Veterans with comorbid posttraumatic stress disorder and major depressive disorder. Pain Med. 2013; 14(10):1529-1533.23924351
9 Seyfried LS, Kales HC, Ignacio RV, Conwell Y, Valenstein M. Predictors of suicide in patients with dementia. Alzheimers Dement. 2011;7(6):567-573.22055973
10 van Ryn M, Phelan SM, Arora NK, Patient-reported quality of supportive care among patients with colorectal cancer in the Veterans Affairs Health Care System. J Clin Oncol. 2014;32(8):809-815.24493712
11 Washington DL, Bean-Mayberry B, Riopelle D, Yano EM. Access to care for women Veterans: delayed healthcare and unmet need. J Gen Intern Med. 2011;26(Suppl 2):655-661.21989618