# APPENDIX S INTERVENTIONS DESIGNED TO REDUCE DISPARITIES (KEY QUESTION 2)

Table Studies Examining Interventions Designed to Reduce Health Disparities in Veteran Populations

Author, Year: Title | Disparity Population; Study Design | Clinical Area | Total N | Type of Intervention: Description of Intervention/Comparator | Outcome Category | Outcomes | Were findings equivalent or positive?
Carmody, 2013: Telephone-delivered cognitive-behavioral therapy for pain management among older military Veterans: a randomized trial^39^ | Age – Older Adults; Trial | Pain | 98 | Technology: Compared Telephone-CBT with telephone-delivered pain education (T-EDU) | Intermediate or Health Outcome | Physical health, depressive symptoms, pain behavior, pain intensity, helpfulness of intervention | Y
Egede, 2015: Psychotherapy for depression in older Veterans via telemedicine: A randomised, open-label, non-inferiority trial^38^ | Age – Older Adults; Trial | Mental health (Depression) | 204 | Technology: Compared the delivery of behavioral activation for depression by in home video conferencing to standard in person. | Intermediate or Health Outcome | Geriatric Depression Scale (GDS), BDI, SCID | Y
O'Toole, 2011: Building care systems to improve access for high-risk and vulnerable Veteran populations^421^ | Age – Older Adults; Observational | General health (utilization) | 167 | System-level: Examined Population-based Patient Centered Medical Home: (1) patient-driven, focused on the patient rather than the disease; (2) team-based; (3) efficient; (4) comprehensive, whole-person oriented care; (5) continuous, with a long-term longitudinal relationship between patient and care team; (6) communication between the Veteran patient and team that is honest, respectful, reliable and culturally sensitive; and (7) coordination across all elements of the healthcare system. Population-specific tailored approach focused on having a fixed site and time of care, eliminating the need for appointments or time-scheduled care episodes. | Utilization | Utilization | Mixed/ Unclear
Zillich, 2008: Quality improvement toward decreasing high-risk medications for older Veteran outpatients^422^ | Age – Older Adults; Observational | Prescribing (high risk) | 2753 | System-level: Examined a multimethod warning system to discourage providers from prescribing high risk medications | Quality | The absence of prescriptions for high risk meds | Y
Ottomanelli, 2013: A prospective examination of the impact of a supported employment program and employment on health-related quality of life, handicap, and disability among Veterans with SCI^63^ | Disability; Trial | Spinal Cord Injuries | 157 | Patient-focused: Compared sites offering SE (integrated vocational and medical rehabilitation treatment, rapid engagement in job finding, competitive employment, inclusion regardless of severity or type of disability, ongoing job support, and focus on participant preferences) to sites offering TAU | Intermediate or Health Outcome | Health-related QOL, functional independence, handicap | Mixed/ Unclear
Belote, 2012: Patient satisfaction as a function of in-house versus contract staffing models in Veterans Affairs community-based outpatient clinics^423^ | Distance; Observational | General healthcare | 543 CBOCs | System-level: Compared VA staffed to contract staffed CBOCs | Patient Evaluation | Patient perceptions of access, continuity of care, courtesy, education and information, emotional support, overall coordination, visit coordination, and patient preferences | Mixed/ Unclear
Desko, 2014: Evaluation of a clinical video telehealth pain management clinic^50^ | Distance; Observational | Pain | 39 | Technology: Evaluated a clinical video telehealth pain management clinic. | Utilization | No show rate | Y
Fortney, 2007: A randomized trial of telemedicine-based collaborative care for depression^69^ | Distance; Trial | Mental health (Depression) | 395 | Multicomponent – System-level, Technology: Compared telemedicine based collaborative care (including CBOCs based in person PCPs and an offsite telepsychiatrists, depression RN care manager, and clinical pharmacists) to usual care. | Intermediate or Health Outcome | Treatment response and remission | Y
Fortney, 2007: A randomized trial of telemedicine-based collaborative care for depression^69^ | Distance; Trial | Mental health (Depression) | 395 | | Patient Evaluation | Patient satisfaction | Y
Fortney, 2007: A randomized trial of telemedicine-based collaborative care for depression^69^ | Distance; Trial | Mental health (Depression) | 395 | | Quality | Antidepressant prescribing and adherence | Y
Knapp, 2011: Interactive internet-based clinical education: an efficient and cost-savings approach to point-of-care test training^48^ | Distance; Observational | HIV (testing) | 36 | Technology: Online in-service teaching clinicians/technicians how to use HIV rapid test | Utilization | Amount of HIV testing 6 months before and 6 months after training | Y
Maciejewski, 2007: Utilization and expenditures of Veterans obtaining primary care in community clinics and VA medical centers: an observational cohort study^375^ | Distance; Observational | General health (utilization) | 61,144 | System-level: Compared outpatient and inpatient utilization of Veterans using CBOCs vs VAMCs | Utilization | Primary care utilization | Mixed/ Unclear
Malhotra, 2014: Comparison of colorectal cancer screening in Veterans based on the location of primary care clinic^424^ | Distance; Observational | Colorectal cancer | 2,837,770 | System-level: Compared CBOCs to VAMCs | Quality | Type of colorectal cancer screening received | Unclear
McKellar, 2012: One-year outcomes of telephone case monitoring for patients with substance use disorder^44^ | Distance; Trial | Mental health (Substance use) | 667 | Technology: Compared telephone case monitoring (TCM) to patients assigned to face-to-face continuing care as usual (CCAU). | Intermediate or Health Outcome | Days abstinent, psychiatric symptoms, quality of life | Y
McKellar, 2012: One-year outcomes of telephone case monitoring for patients with substance use disorder^44^ | Distance; Trial | Mental health (Substance use) | 667 | Technology: Compared telephone case monitoring (TCM) to patients assigned to face-to-face continuing care as usual (CCAU). | Patient Evaluation | Patient satisfaction | Y
Mohr, 2011: Telephone-administered cognitive behavioral therapy for Veterans served by community-based outpatient clinics^35^ | Distance; Trial | Mental Health (Depression) | 85 | Technology: Compared telephone-CBT to TAU at CBOCs | Intermediate or Health Outcome | Depression severity | N
Nelson, 2012: The effect of increased travel reimbursement rates on health care utilization in the VA^425^ | Distance; Observational | General health (utilization) | 192,559 | System-level: Compared pre-travel reimbursement rate increase to post increase | Utilization | Types of healthcare utilization: (1) outpatient, (2) inpatient, and (3) pharmacy services | Y
Nelson, 2014: Utilization of travel reimbursement in the Veterans Health Administration^426^ | Distance; Observational | General health (utilization) | 214,376 | System-level: Compared pre-travel reimbursement rate increase to 2 later increases | Utilization | Utilization of reimbursement | Mixed/ Unclear
Singh, 2015: Implementation and outcomes of a pharmacist-managed clinical video telehealth anticoagulation clinic^45^ | Distance; Observational | Anticoagulation | 38 | Technology: Examined a pharmacist managed clinical video telehealth anticoagulation clinic | Intermediate or Health Outcome | International Normalized Ratio (INR), time in therapeutic range (TTR) | Y
Singh, 2015: Implementation and outcomes of a pharmacist-managed clinical video telehealth anticoagulation clinic^45^ | Distance; Observational | Anticoagulation | 38 | Technology: Examined a pharmacist managed clinical video telehealth anticoagulation clinic | Patient Evaluation | Patient satisfaction | Y
Wakefield, 2014: Feasibility and effectiveness of remote, telephone-based delivery of cardiac rehabilitation^46^ | Distance; Trial | CV disease | 55 | Technology: Compared home/telephone cardiac rehabilitation to face-to-face | Intermediate or Health Outcome | Ejection fraction, blood pressure, pulse, and lipids; weight, body mass index, medication adherence, depressive symptoms; quality of life, adverse events | Y
Wakefield, 2014: Feasibility and effectiveness of remote, telephone-based delivery of cardiac rehabilitation^46^ | Distance; Trial | CV disease | 55 | Technology: Compared home/telephone cardiac rehabilitation to face-to-face | Utilization | CR program completion, hospitalizations and urgent care visits | Y
Brief, 2013: Web intervention for OEF/OIF Veterans with problem drinking and PTSD symptoms: a randomized clinical trial^43^ | Era of Service; Trial | Mental health (Substance use, PTSD) | 600 | Technology: Compared online self-management intervention (VetChange) to a delayed intervention group | Intermediate or Health Outcome | Quantity & frequency of drinking (Quick Drink Screen), alcohol-related problems (Short Inventory of Problems), PTSD symptoms (PTSD-Checklist 5) | Y
Seal, 2011: Reducing barriers to mental health and social services for Iraq and Afghanistan Veterans: Outcomes of an integrated primary care clinic^427^ | Era of Service; Observational | Mental health | 526 | System-level: Compared integrated (primary, mental health, social services) to usual care. Integrated care (intervention): PCPs in the IC clinic conduct an health history & physical focused on deployment-and post-deployment-related medical and psychosocial problems. Following the PCP visit, patients in the IC clinic meet with a mental health provider, the “Post-Deployment Stress Specialist,” and social worker, the “Combat Case Manager” who all deliver specialized services. Usual care (control): Pts receive standard health history & physical. Unless a patient screens positive for PTSD or depression or makes a specific request, patients in the UC clinic are not routinely evaluated by a psychologist or social worker on the same day as their first primary care visit. | Utilization | Same-day or within 30-day initial mental health evaluation, initial social services evaluation within 30 days, number of “follow-up” specialty mental health visit(s) within 1 year | Y
Stecker, 2014: RCT of a brief phone-based CBT intervention to improve PTSD treatment utilization by returning service members^42^ | Era of Service; Trial | Mental Health (PTSD) | 300 | Technology: Compared brief phone based CBT to control. | Intermediate or Health Outcome | Perceptions about services, depression, and PTSD severity | Y
Stecker, 2014: RCT of a brief phone-based CBT intervention to improve PTSD treatment utilization by returning service members^42^ | Era of Service; Trial | Mental Health (PTSD) | 300 | Technology: Compared brief phone based CBT to control. | Utilization | Treatment engagement, initiation after study and number of sessions at 1, 3, 6 months | Y
McGuire, 2009: Access to primary care for homeless Veterans with serious mental illness or substance abuse: a follow-up evaluation of co-located primary care and homeless social services^428^ | Homeless/SES; Observational | General Health | 260 | System-level: Compared the Mental Health Outpatient Treatment Center (MHOTC) to usual care. The MHOTC integrates homeless, primary care, and mental health services in the same building. Homeless Veterans were evaluated in a screening clinic and quickly referred to all needed services within the MHOTC building. The goal of the MHOTC was to have the initial primary care appointment occur the same day that the homeless Veteran came to the screening clinic (ie, the first day of arrival at the screening clinic). Case managers from the Homeless Program provided short-term case management upon entry to the MHOTC. | Intermediate or Health Outcome | Health status | N
McGuire, 2009: Access to primary care for homeless Veterans with serious mental illness or substance abuse: a follow-up evaluation of co-located primary care and homeless social services^428^ | Homeless/SES; Observational | General Health | 260 | | Utilization | Primary care enrollment | Y
McInnes, 2014: Retaining homeless Veterans in outpatient care: a pilot study of mobile phone text message appointment reminders^41^ | Homeless/SES; Observational | Utilization | 21 | Technology: Examined text message appointment reminders 5 and 2 days before scheduled appointments | Utilization | Cancelled appointments, no-shows, ED use, hospitalizations | Y
O'Toole, 2011: Building care systems to improve access for high-risk and vulnerable Veteran populations^421^ | Homeless/SES;Observational | General health (utilization) | 71 | System-level: Examined Population-based Patient Centered Medical Home: (1) patient-driven, focused on the patient rather than the disease; (2) team-based; (3) efficient; (4) comprehensive, whole-person oriented care; (5) continuous, with a long-term longitudinal relationship between patient and care team; (6) communication between the Veteran patient and team that is honest, respectful, reliable, and culturally sensitive; and (7) coordination across all elements of the healthcare system. Population-specific tailored approach focused on having a fixed site and time of care, eliminating the need for appointments or time-scheduled care episodes. | Utilization | Utilization | Mixed/ Unclear
Chrystal, 2015: Experience of primary care among homeless individuals with mental health conditions^429^ | Homeless; Observational | Primary care | 366 | System-level: Homeless-specific service tailoring of clinic site | Patient Evaluation | Primary care experience | Y
Gabrielian, 2014: VA health service utilization for homeless and low-income Veterans: a spotlight on the VA Supportive Housing (VASH) program in greater Los Angeles^399^ | Homeless; Observational | General health (utilization) | 62,459 | System-level: Compared HUD-VASH participants to homeless Veterans. HUD-VASH is a Housing First program that offers vouchers and supportive services to mobilize homeless Veterans into community rental units. | Utilization | Utilization: outpatient, inpatient, ED, mental health, preventable hospitalizations | Y
Kertesz, 2013: Comparing homeless persons' care experiences in tailored versus nontailored primary care programs^430^ | Homeless; Observational | Primary care | 601 | System-level: Compared homeless-tailored to non-homeless tailored primary care | Patient Evaluation | Experience of care in clinics tailored towards homeless patients vs clinics not tailored. | Y
O'Connell, 2009: Direct placement versus multistage models of supported housing in a population of Veterans who are homeless^431^ | Homeless; Observational | Mental health (general, substance use) | 322 | System-level: 2 models of supported housing combined with ready access to rent subsidies: Direct placement housing vs multistage housing | Intermediate or Health Outcome | Psychiatric symptoms, alcohol and drug use, social support, and quality of life | N
O'Connell, 2009: Direct placement versus multistage models of supported housing in a population of Veterans who are homeless^431^ | Homeless; Observational | Mental health (general, substance use) | 322 | System-level: 2 models of supported housing combined with ready access to rent subsidies: Direct placement housing vs multistage housing | Utilization | Service utilization & cost | Y
O'Connell, 2012: Differential impact of supported housing on selected subgroups of homeless Veterans with substance abuse histories^36^ | Homeless; Trial | Mental Health | 259 | System-level: Compared U.S. Department of Housing and Urban Development–Veterans Affairs Supported Housing (HUD-VASH) to intensive case management (ICM) or usual care. | Intermediate or Health Outcome | Health-related QOL, drug and alcohol use, psychotic symptom severity, | Mixed/ Unclear
O'Toole, 2010: Applying the chronic care model to homeless Veterans of a population approach to primary care on utilization and clinical outcomes^432^ | Homeless; Observational | Primary care | 177 | System-level: Compared homeless-oriented primary care clinics to general internal medicine clinics | Intermediate or Health Outcome | Blood pressure, HbA1c LDL for hyperlipidemia | Y
O'Toole, 2010: Applying the chronic care model to homeless Veterans of a population approach to primary care on utilization and clinical outcomes^432^ | Homeless; Observational | Primary care | 177 | System-level: Compared homeless-oriented primary care clinics to general internal medicine clinics | Utilization | Primary care visits, ED, hospitalizations | Y
O'Toole, 2015: Tailoring outreach efforts to increase primary care use among homeless Veterans: results of a randomized controlled trial^56^ | Homeless; Trial | General health (utilization) | 185 | Patient-focused: Four arms – compared a personal health assessment (PHA) and brief (MI) intervention (BI) to a clinic orientation to PHAl/BI + clinic orientation to usual care | Utilization | Primary care, mental health, specialty care visits | Y
Smelson, 2013: A wraparound treatment engagement intervention for homeless Veterans with co-occurring disorders^68^ | Homeless; Trial | Mental health (substance use) | 333 | Multicomponent – System-level, Patient-focused: Compared Maintaining Independence and Sobriety through Systems Integration, Outreach, and Networking (MISSION) to usual care. MISSION is a low-intensity wrap-around intervention that engages homeless Veterans with co-occurring disorders in care. MISSION consisted of 4 components: 1) integrated mental health & SUDs treatment, 2) case management, 3) peer support, and 4) vocational support. | Intermediate or Health Outcome | Behavioral health outcomes, substance use | Mixed/ Unclear
Smelson, 2013: A wraparound treatment engagement intervention for homeless Veterans with co-occurring disorders^68^ | Homeless; Trial | Mental health (substance use) | 333 | | Utilization | Treatment engagement, rehospitalization | Y
Winn, 2013: Housing assistance and case management: improving access to substance use disorder treatment for homeless Veterans^59^ | Homeless; Observational | Mental health (Substance use) | 211 | Patient-focused: Compared Transitional Supportive Housing and Case Management (TSH-CM) to early-recovery therapy group (ERG). TSH-CM is an intervention for Veterans on the waiting list for intensive outpatient addiction treatment. A case manager met with homeless Veterans, created integrated diagnostic summaries, and connected Veterans to local community partners for housing. ERG provided group support while waitlisted and a nurse practitioner to provide medication management services. | Utilization | Percentage of Veterans admitted to treatment | Y
Kilbourne, 2011: Does colocated care improve access to cardiometabolic screening for patients with serious mental illness?^433^ | Mental Health; Observational | Primary care | 40,600 | System-level: Compared colocated (mental health/general health) to non-colocated clinics | Quality | Receipt of screening for cardiometabolic factors (lipids, glucose, BMI, blood pressure) | Y
Kilbourne, 2011: Quality of general medical care among patients with serious mental illness: does colocation of services matter?^434^ | Mental Health; Observational | Primary care | 7514 | System-level: Compared colocated (mental health/general health) to non-colocated clinics | Quality | Completion of preventive care, adequacy of hypertension/lipid/diabetes care; EPRP quality indicators for common processes of care | Mixed/ Unclear
Kilbourne, 2013: Randomized controlled trial to assess reduction of cardiovascular disease risk in patients with bipolar disorder: the Self-Management Addressing Heart Risk Trial (SMAHRT)^61^ | Mental Health; Trial | Cardiovascular disease | 118 | Patient-focused: Compared Life Goals Collaborative Care (LGCC; based on the Chronic Care Model but places an emphasis on self-management through targeted health behavior change strategies to address the psychosocial origins of CVD risk factors) to enhanced usual care | Intermediate or Health Outcome | Primary = systolic and diastolic blood pressure, non-fasting total cholesterol, and physical health-related quality of life. Secondary = non-fasting high-density lipoprotein levels (HDLs), and direct low-density lipoprotein levels (LDLs), weight, including body mass index (BMI), waist circumference, Framingham risk score, mental health-related quality of life based on the SF-12, functioning, and psychiatric symptoms. | Y
McFall, 2010: Integrating tobacco cessation into mental health care for posttraumatic stress disorder: a randomized controlled trial^37^ | Mental Health; Trial | Smoking | 943 | System-level: Compared smoking cessation integrated into mental health vs referral to a smoking cessation clinic. Control: Smoking cessation clinic, which was a referral to specialized cessation clinics at each site and represented the usual standard of care within the VA. | Intermediate or Health Outcome | Smoking cessation: 12-month bioverified prolonged abstinence (primary outcome) and 7- and 30-day point prevalence abstinence assessed at 3-month intervals Other outcomes: PTSD severity (CAPS, PTSD checklist), depression (PHQ-9) | Y
McKellar, 2012: One-year outcomes of telephone case monitoring for patients with substance use disorder^44^ | Mental Health; Trial | Mental health (Substance use) | 667 | Technology: Compared telephone case monitoring (TCM) to patients assigned to face-to-face continuing care as usual (CCAU) | Intermediate or Health Outcome | Days abstinent, psychiatric symptoms, quality of life | Y
McKellar, 2012: One-year outcomes of telephone case monitoring for patients with substance use disorder^44^ | Mental Health; Trial | Mental health (Substance use) | 667 | Technology: Compared telephone case monitoring (TCM) to patients assigned to face-to-face continuing care as usual (CCAU) | Patient Evaluation | Patient satisfaction | Y
O'Toole, 2011: Building care systems to improve access for high-risk and vulnerable Veteran populations^421^ | Mental Health; Observational | General health (utilization) | 74 | System-level: Examined Population-based Patient Centered Medical Home: (1) patient-driven, focused on the patient rather than the disease; (2) team-based; (3) efficient; (4) comprehensive, whole-person oriented care; (5) continuous, with a long-term longitudinal relationship between patient and care team; (6) communication between the Veteran patient and team that is honest, respectful, reliable, and culturally sensitive; and (7) coordination across all elements of the healthcare system. Population-specific tailored approach focused on having a fixed site and time of care, eliminating the need for appointments or time-scheduled care episodes. | Utilization | Utilization | Mixed/ Unclear
Pirraglia, 2011: Colocated general medical care and preventable hospital admissions for Veterans with serious mental illness^435^ | Mental Health; Observational | Primary care | 92,268 | System-level: Compared colocated (mental health/general health) to non-colocated clinics | Utilization | Hospitalizations for ambulatory care-sensitive conditions | Y
Pomerantz, 2008: Improving efficiency and access to mental health care: combining integrated care and advanced access^436^ | Mental Health; Observational | Mental health (utilization) | 987 | System-level: Redesigned system to better integrate mental health into primary care (ie, Primary Mental Health Clinic (PMHC)). The PMHC is based on the following principles: 1) Clinic Mental health providers should be part of the primary care team to assure easy access to assessment and treatment. 2) Care should be flexible to meet the needs of providers and patients. 3) Access to care should be immediate, with no scheduled appointments. 4) Most patients should be able to receive all the mental health care they need without referral into more comprehensive care. | Patient Evaluation | Patient satisfaction | Y
Pomerantz, 2008: Improving efficiency and access to mental health care: combining integrated care and advanced access^436^ | Mental Health; Observational | Mental health (utilization) | 987 | | Utilization | Wait time, patients coming to first appointment, referrals to specialty care, loss of productivity (cancellations and no-shows), number of patients seen | Y
Szymanski, 2013: Integrated care: treatment initiation following positive depression screens^437^ | Mental Health; Observational | Mental Health (Depression) | 36,263 | System-level: Compared receiving integrated primary care-mental health services on the same day as a depression diagnosis was associated with initiation of depression treatment as compared to receiving just primary care services alone | Utilization | Initiation of depression treatment | Y
Turchik, 2014: Preferences for gender-targeted health information: a study of male Veterans who have experienced military sexual trauma^34^ | Mental Health; Trial | Mental Health (Military Sexual Trauma) | 173 | Patient-focused: Compared gender-neutral or gender-targeted psychoeducational information on MST, or information on an unrelated topic (influenza vaccination), in the mail | Utilization | Mental health utilization | N
Allen, 2011: Tailoring coping skills training for African Americans with osteoarthritis^66^ | Race (AA/Black); Observational | Osteoarthritis | 30 | Multicomponent – Patient-focused, Technology: Examined Coping Skills Training: one in-person session and 9 weekly telephone calls. Intervention sessions involved teaching coping skills (eg, cognitive restructuring, relaxation, imagery, and activity pacing) and providing guidance for home practice and use of coping skills during daily life situations | Intermediate or Health Outcome | Pain and functioning (assessed using Arthritis Impact Measurement Scales-2, Arthritis Self-Efficacy Scale, and Coping Strategies Questionnaire) | Y
Houston, 2016: Using stories to address disparities in hypertension^60^ | Race (AA/Black); Trial | Cardiovascular | 618 | Patient-focused: 2-arm, randomized control trial to improve HTN control, comparing the “Stories” DVD with a control didactic, non-narrative educational DVD | Intermediate or Health Outcome | SBP, BP difference | Y
Ibrahim, 2013: Willingness and access to joint replacement among African American patients with knee osteoarthritis: a randomized, controlled intervention^64^ | Race (AA/Black); Trial | Orthopedic | 639 | Patient-focused: Compared 1) a decision aid, 2) motivational interviewing, and 3) a decision aid + motivational interviewing to 4) attention control | Patient Factors | Changes in patient willingness; knowledge and expectations of TKR, discussions of knee pain with PCP, referral to an orthopedic clinic, or saw an orthopedic surgeon. | Y
Ibrahim, 2013: Willingness and access to joint replacement among African American patients with knee osteoarthritis: a randomized, controlled intervention^64^ | Race (AA/Black); Trial | Orthopedic | 639 | Patient-focused: Compared 1) a decision aid, 2) motivational interviewing, and 3) a decision aid + motivational interviewing to 4) attention control | Quality | Referral to an orthopedic clinic, or saw an orthopedic surgeon | Y
Ibrahim, 2013: Willingness and access to joint replacement among African American patients with knee osteoarthritis: a randomized, controlled intervention^64^ | Race (AA/Black); Trial | Orthopedic | 639 | Patient-focused: Compared 1) a decision aid, 2) motivational interviewing, and 3) a decision aid + motivational interviewing to 4) attention control | Utilization | Attend an orthopedic surgery consult | Y
Kressin, 2016: A brief, multifaceted, generic intervention to improve blood pressure control and reduce disparities had little effect^67^ | Race (AA/Black); Observational | Cardiovascular | 8,866 | Multicomponent – System-level, Provider-focused: Compared 1) EMR reminder to 2) EMR reminder plus provider training on patient centered related to medication adherence and hypertension care to 3) usual care | Intermediate or Health Outcome | Blood pressure | Mixed
Kressin, 2016: A brief, multifaceted, generic intervention to improve blood pressure control and reduce disparities had little effect^67^ | Race (AA/Black); Observational | Cardiovascular | 8,866 | | Quality | Medication adherence, patient provider interaction | Mixed
Long, 2012: Peer mentoring and financial incentives to improve glucose control in African American Veterans: a randomized trial^62^ | Race (AA/Black); Trial | Diabetes | 117 | Patient-focused: Compared 1) peer mentoring, 2) a financial incentive to 3) usual care for HbA1c control | Intermediate or Health Outcome | HbA1c | Y
Petersen, 2016: Impact of a pay-for-performance program on care for black patients with hypertension: important answers in the era of the Affordable Care Act^52^ | Race (AA/Black); Trial | Cardiovascular | 67 | Provider-focused: Compared 3 types of financial incentives (1) physician-level (individual) incentives; (2) practice-level incentives; (3) physician- and practice-level (combined) incentives to (4) no incentives (control) | Intermediate or Health Outcome | The proportion of patients who achieved blood pressure control or received an appropriate response to uncontrolled blood pressure | Y
Weng, 2007: Development of a decision aid to address racial disparities in utilization of knee replacement surgery^65^ | Race (AA/Black); Observational | Osteoarthritis | 64 | Patient-focused: Evaluated an educational videotape and tailored TKR decision aid designed to reduce disparities in TKR knowledge and expectations | Patient Factors | Change in expectations about postoperative TKR pain and change in expectations about postoperative TKR physical function, decision readiness, willingness to consider TKR | Y
Shore, 2008: Acceptability of telepsychiatry in American Indians^40^ | Race (AI/AN); Trial | Mental health | 53 | Technology: Compared the administration of the SCID in person to interactive video conferencing | Patient Evaluation | Patient satisfaction | Y
Davis, 2014: Teleneurology: successful delivery of chronic neurologic care to 354 patients living remotely in a rural state^51^ | Rural; Observational | Neurology | 354 | Technology: Neuro telemedicine visits at CBOCs vs in-clinic visits at urban centers for rural Veterans | Intermediate or Health Outcome | Number of neuro-condition-related ER visits | Y
Davis, 2014: Teleneurology: successful delivery of chronic neurologic care to 354 patients living remotely in a rural state^51^ | Rural; Observational | Neurology | 354 | Technology: Neuro telemedicine visits at CBOCs vs in-clinic visits at urban centers for rural Veterans | Utilization | No show rate | Y
Fortney, 2015: Telemedicine-based collaborative care for posttraumatic stress disorder: a randomized clinical trial^438^ | Rural; Trial | Mental health (PTSD) | 265 | Technology: Compared telemedicine PTSD cognitive processing therapy (ie, telephone, interactive video, and shared electronic medical records) to usual care. | Intermediate or Health Outcome | PTSD severity, depression severity, health-related QOL | Y
Fortney, 2015: Telemedicine-based collaborative care for posttraumatic stress disorder: a randomized clinical trial^438^ | Rural; Trial | Mental health (PTSD) | 265 | Technology: Compared telemedicine PTSD cognitive processing therapy (ie, telephone, interactive video, and shared electronic medical records) to usual care. | Quality | Medication adherence | Y
Hilgeman, 2014: Alabama Veterans Rural Health Initiative: a pilot study of enhanced community outreach in rural areas^58^ | Rural; Trial | General health (utilization) | 203 | Patient-focused: Compared enhanced enrollment and engagement outreach (EEE = motivational interview, education, and patient navigation) to administrative outreach (AO = VHA enrollment document package without education, patient navigation, or motivational interview) | Utilization | VA appointment dates | Y
Mahaney-Price, 2014: Enabling advance directive completion by rural Alabama Veterans: a pilot study^57^ | Rural; Trial | General health (end of life) | 50 | Patient-focused: Compared Nurse-Supported Advance Care Planning Intervention (a manualized education, support, and guidance session provided by a RN that included information about risks, benefits, and alternatives of specific choices) to usual care (informational session with a social worker). | Patient factors | Veterans' satisfaction with the intervention | Y
Mahaney-Price, 2014: Enabling advance directive completion by rural Alabama Veterans: a pilot study^57^ | Rural; Trial | General health (end of life) | 50 | | Quality | Advance Directive completion rates | Y
McFarland, 2012: Implementation of an education and skills programme in a teledermatology project for rural Veterans^55^ | Rural; Observational | Dermatology | 94 | Multicomponent - Provider-focused, Technology: Examined a teledermatology project providing co-managed care and a continuing education programme to improve access to dermatology care for rural Veterans. After 2 years of educational programmes, more primary care providers were competent to perform basic dermatology procedures and diagnose uncomplicated conditions. | Utilization | Patient referrals for dermatology care | Y
Mohamed, 2013: Adaptation of intensive mental health intensive case management to rural communities in the Veterans Health Administration^439^ | Rural; Observational | Mental health (general) | 3,420 | System-level: Compared Rural Access Networks for Growth Enhancement (RANGE) to Mental Health Intensive Case Management (MHICM) | Intermediate or Health Outcome | MH outcomes (SI etc.) | Mixed
Mohamed, 2013: Adaptation of intensive mental health intensive case management to rural communities in the Veterans Health Administration^439^ | Rural; Observational | Mental health (general) | 3,420 | System-level: Compared Rural Access Networks for Growth Enhancement (RANGE) to Mental Health Intensive Case Management (MHICM) | Patient Evaluation | Overall satisfaction | Y
Mohamed, 2013: Adaptation of intensive mental health intensive case management to rural communities in the Veterans Health Administration^439^ | Rural; Observational | Mental health (general) | 3,420 | System-level: Compared Rural Access Networks for Growth Enhancement (RANGE) to Mental Health Intensive Case Management (MHICM) | Utilization | Service delivery/quality: face-to-face treatment intensity; receiving rehabilitation services; crisis intervention; substance abuse treatment | Y
Morland, 2010: Telemedicine for anger management therapy in a rural population of combat Veterans with posttraumatic stress disorder: a randomized noninferiority trial^440^ | Rural; Trial | Mental health (PTSD) | 125 | Technology: Compared group CBT-based anger management therapy delivered in person or via video conferencing | Intermediate or Health Outcome | PTSD symptoms (anger) | Y
Morland, 2010: Telemedicine for anger management therapy in a rural population of combat Veterans with posttraumatic stress disorder: a randomized noninferiority trial^440^ | Rural; Trial | Mental health (PTSD) | 125 | Technology: Compared group CBT-based anger management therapy delivered in person or via video conferencing | Quality | Processes, alliance | Y
Morland, 2014: Cognitive processing therapy for posttraumatic stress disorder delivered to rural Veterans via telemental health: a randomized noninferiority clinical trial^441^ | Rural; Trial | Mental Health (PTSD) | 125 | Technology: Compared cognitive processing therapy-cognitive only version (CPT-C) delivered via videoteleconferencing (VTC) to in person CPT-C | Intermediate or Health Outcome | PTSD symptoms | Y
Morland, 2014: Cognitive processing therapy for posttraumatic stress disorder delivered to rural Veterans via telemental health: a randomized noninferiority clinical trial^441^ | Rural; Trial | Mental Health (PTSD) | 125 | Technology: Compared cognitive processing therapy-cognitive only version (CPT-C) delivered via videoteleconferencing (VTC) to in person CPT-C | Patient Evaluation | Patient satisfaction | Y
Morland, 2014: Cognitive processing therapy for posttraumatic stress disorder delivered to rural Veterans via telemental health: a randomized noninferiority clinical trial^441^ | Rural; Trial | Mental Health (PTSD) | 125 | Technology: Compared cognitive processing therapy-cognitive only version (CPT-C) delivered via videoteleconferencing (VTC) to in person CPT-C | Patient factors | Therapeutic alliance, treatment expectancies | Y
Morland, 2014: Cognitive processing therapy for posttraumatic stress disorder delivered to rural Veterans via telemental health: a randomized noninferiority clinical trial^441^ | Rural; Trial | Mental Health (PTSD) | 125 | Technology: Compared cognitive processing therapy-cognitive only version (CPT-C) delivered via videoteleconferencing (VTC) to in person CPT-C | Quality | Treatment compliance | Y
Nelson, 2012: The effect of increased travel reimbursement rates on health care utilization in the VA^425^ | Rural; Observational | General health (utilization) | 192,559 | System-level: Compared pre-travel reimbursement rate increase to post increase | utilization | Types of healthcare utilization: (1) outpatient, (2) inpatient, and (3) pharmacy services | Y
Nelson, 2014: Utilization of travel reimbursement in the Veterans Health Administration^426^ | Rural; Observational | General health (utilization) | 214,376 | System-level: Compared pre-travel reimbursement rate increase to 2 later increases | Utilization | Utilization of reimbursement | Mixed/ Unclear
Ohl, 2013: Mixed-methods evaluation of a telehealth collaborative care program for persons with HIV infection in a rural setting^47^ | Rural; Observational | HIV (management) | 25 | Technology: Evaluated a telehealth collaborative care (TCC) program for persons with HIV in a rural areas | Quality | Veterans Affairs (VA) healthcare system performance measures for care for HIV infection and common comorbidities, patient travel time to obtain care, and patient satisfaction. | Y
Tan, 2013: Improving access to care for women Veterans suffering from chronic pain and depression associated with trauma^49^ | Rural; Observational | Comorbid chronic pain & depression/PT SD | 34 | Technology: Examined combined biofeedback training and education/support group therapy delivered via videoteleconferencing. | Intermediate or Health Outcome | Symptoms of pain, depression, PTSD, sleep disturbance as well as acceptability of treatment | Y
Turner, 2012: A pilot trial of neuropsychological evaluations conducted via telemedicine in the Veterans Health Administration^442^ | Rural; Trial | Neuropsycholo gy | 15 | Technology: Compared telemedicine to in-person neuropsychological evaluations | Quality | Patient preferences, diagnoses, follow-up | Y
Bastian, 2014: Association between women Veterans' experiences with VA outpatient health care and designation as a women's health provider in primary care clinics^443^ | Women; Observational | Primary care | 3,147 | System-level: Compared designated women's health providers (DWHP) to non-DWHPs | Patient Evaluation | Patient experience | Y
Fox, 2016: Effectiveness of an evidence-based quality improvement approach to cultural competence training: the Veterans Affairs' “Caring for Women Veterans” program^54^ | Women; Trial | General healthcare | 84 | Provider-focused: Compared a local adapted evidence-based quality improvement (EBQI) version of the Caring for Women Veterans provider training to the standard implementation (SI) arm | Quality | Gender sensitivity & knowledge scales | Y
Gray, 2015: Gynecologists in the VA: do they enhance availability of sex-specific services and policies in the emergency department?^444^ | Women; Observational | Women's Health | 120 | System-level: Compared EDs with >=.5 to < .5 gynecologist FTE | Utilization | Availability of sex-specific ED services, availability of gynecology services (on-site ED gynecology consultations and gynecologist follow-up within VA), sex specific pharmaceutical interventions [emergency contraception and rho (D) immunoglobulin], sex-specific radiology services (pelvic ultrasound by a licensed technician or radiologist), and the presence of transfer policies for obstetric and gynecologic emergencies. | Y
O'Toole, 2011: Building care systems to improve access for high-risk and vulnerable Veteran populations^421^ | Women; Observational | General health (utilization) | 145 | System-level: Examined Population-based Patient Centered Medical Home: (1) patient-driven, focused on the patient rather than the disease; (2) team-based; (3) efficient; (4) comprehensive, whole-person oriented care; (5) continuous, with a long-term longitudinal relationship between patient and care team; (6) communication between the Veteran patient and team that is honest, respectful, reliable and culturally sensitive; and (7) coordination across all elements of the healthcare system. Population-specific tailored approach focused on having a fixed site and time of care, eliminating the need for appointments or time-scheduled care episodes. | Utilization | Utlization | Y
Sambamoorthi, 2010: Organization of care and diagnosed depression among women Veterans^445^ | Women; Observational | Mental health (Depression) | 27,972 | System-level: Integrated mental health in women's primary care clinics | Intermediate or Health Outcome | Diagnosed depression | Y
Vogt, 2008: Toward gender-aware health care: evaluation of an intervention to enhance care for female patients in the VA setting^53^ | Women; Trial | General healthcare | 158 | Provider-focused: Compared a 30-minute computerized educational program targeting deficits in the gender awareness domains of gender-role ideology, sensitivity, and knowledge to a program on managing stress in the workplace (control). | Quality | Gender-awareness inventory-VA which included gender-role ideology, sensitivity, and knowledge domains. | Mixed
Washington, 2011: Tailoring VA primary care to women Veterans: association with patient-rated quality and satisfaction^446^ | Women; Observational | Primary care | 1,749 | System-level: Compared VAMCs and CBOCs where there are designated primary care providers for women and/or comprehensive women's health centers (adopter sites) to sites with primary care providers for women or comprehensive women's health centers. | Patient Evaluation | Gender-related satisfaction, gender appropriateness, perceptions of VA provider skills, quality of care | Mixed