# APPENDIX R HEALTH DISPARITIES AMONG HOMELESS VETERANS

Evidence Map Health Disparities Among Homeless Veterans

Legend: The bubble plot shows the number of studies identified (y-axis) that provided evidence of no disparity, mixed or unclear findings, or a disparity (x-axis) for each outcome category (utilization, quality, patient health outcomes). Quality of care studies included processes of care, intermediate outcomes, and patient evaluations of care. Bubble size represents the mean confidence score, with a range of -1 to 4.

Table Health Disparities Among Homeless Veterans

Author, Year: Title | Clinical area | Total N | Category | Outcomes | Disparity | Confidence
Doran, 2013: What drives frequent emergency department use in an integrated health system? National data from the Veterans Health Administration^275^ | Utilization (ED) | 5531379 | Utilization | VHA ED utilization | Yes | 3
Fasoli, 2010: Predisposing characteristics, enabling resources and need as predictors of utilization and clinical outcomes for Veterans receiving mental health services^280^ | Mental health (multiple) | 421 | Utilization | Mental health utilization (outpatient, inpatient, residential) | Mixed/ Unclear | 2
Fasoli, 2010: Predisposing characteristics, enabling resources and need as predictors of utilization and clinical outcomes for Veterans receiving mental health services^280^ | Mental health (multiple) | 421 | Health Outcome | GAF, self-reported mental health (BASIS-24) | No | 2
Gabrielian, 2014: VA health service utilization for homeless and low-income Veterans: a spotlight on the VA Supportive Housing (VASH) program in greater Los Angeles^399^ | Utilization | 62459 | Utilization | Differences in service utilization (primary care, hospital, mental health, specialty) | Yes | 1
Irmiter, 2007: Reinstitutionalization following psychiatric discharge among VA patients with serious mental illness: a national longitudinal study^158^ | Mental health (serious mental illness) | 35527 | Health Outcome | Time to reinstitutionalization/rehospitalization | Yes | 1
O'Toole, 2013: New to care: demands on a health system when homeless Veterans are enrolled in a medical home model^419^ | Utilization | 233 | Utilization | Utilization: primary care, mental health, specialty care, ED | Yes | 0
Tsai, 2013: When health insurance is not a factor: national comparison of homeless and nonhomeless US Veterans who use Veterans Affairs Emergency Departments^420^ | Utilization, mental and physical health | 930712 | Utilization | ED utilization | Yes | 3
Tsai, 2013: When health insurance is not a factor: national comparison of homeless and nonhomeless US Veterans who use Veterans Affairs Emergency Departments^420^ | Utilization, mental and physical health | 930712 | Quality | Psychotropic medication | Yes | 2
Tsai, 2013: When health insurance is not a factor: national comparison of homeless and nonhomeless US Veterans who use Veterans Affairs Emergency Departments^420^ | Utilization, mental and physical health | 930712 | Health Outcome | Physical conditions and mental health | Mixed/Unclear | 3
Zeber, 2007: Self-reported access to general medical and psychiatric care among Veterans with bipolar disorder^249^ | Mental health (Bipolar) | 435 | Utilization | Patient perception of access to health and mental health | Yes | 0