# APPENDIX Q HEALTH DISPARITIES AMONG LGBT VETERANS

Evidence Map Health Disparities Among LGBT Veterans

Abbreviations: LGBT = lesbian, gay, bisexual, and transgender.

Legend: The bubble plot shows the number of studies identified (y-axis) that provided evidence of no disparity, mixed or unclear findings, or a disparity (x-axis) for each outcome category (utilization, quality, patient health outcomes). Quality of care studies included processes of care, intermediate outcomes, and patient evaluations of care. Bubble size represents the mean confidence score, with a range of -1 to 4.

Table Health Disparities Among LGBT Veterans

Author, Year: Title | Clinical area | Total N | Category | Outcomes | Disparity | Confidence
Alessi, 2013: PTSD and sexual orientation: an examination of criterion A1 and non-criterion A1 events^412^ | Mental health (PTSD) | 38 | Health Outcome | Lifetime prevalence of PTSD (DSM IV-TR criterion) | No | 0
Blosnich, 2013: Health care utilization and health indicators among a national sample of U.S. Veterans in same-sex partnerships^413^ | General health | 13927 | Utilization | VHA utilization | No | 2
Blosnich, 2013: Health care utilization and health indicators among a national sample of U.S. Veterans in same-sex partnerships^413^ | General health | 13927 | Health Outcome | Health status | No | 2
Blosnich, 2013: Health disparities among sexual minority women Veterans^414^ | General health | 1908 | Quality | Overweight, obesity, activity limitations, poor sleep | Mixed/ Unclear | 1
Blosnich, 2013: Health disparities among sexual minority women Veterans^414^ | General health | 1908 | Health Outcome | Frequent mental distress, low satisfaction with life, >14 days poor physical health, disability requiring assistive device | Mixed/ Unclear | 1
Blosnich, 2013: Physical health indicators among lesbian, gay, and bisexual US Veterans^26^ | General health | 11665 | Utilization | Access | No | 2
Blosnich, 2013: Physical health indicators among lesbian, gay, and bisexual US Veterans^26^ | General health | 11665 | Quality | Flu shot in past 12 months, HIV test | No | 2
Blosnich, 2013: Physical health indicators among lesbian, gay, and bisexual US Veterans^26^ | General health | 11665 | Health Outcome | Health-related QOL | No | 2
Blosnich, 2014: Suicidality among Veterans: implications of sexual minority status^415^ | Mental health (Suicidality) | 444 | Health Outcome | Suicidal ideation and attempts | Mixed/ Unclear | 1
Brown, 2015: Mental health and medical health disparities in 5135 transgender Veterans receiving healthcare in the Veterans Health Administration: a case-control study^25^ | Mental health | 20540 | Health Outcome | Mental and physical health diagnoses | Mixed/ Unclear | 2
Lehavot, 2014: Examining sexual orientation disparities in alcohol misuse among women Veterans^416^ | Mental health (substance use disorder) | 699 | Health Outcome | Alcohol misuse, PTSD, depressive symptoms | Yes | 1
Lehavot, 2014: Trauma, posttraumatic stress disorder, and depression among sexual minority and heterosexual women Veterans^417^ | Mental health (PTSD and Depression) | 706 | Health Outcome | PTSD, depression diagnoses | Mixed/ Unclear | -1
Mattocks, 2013: Sexual victimization, health status, and VA healthcare utilization among lesbian and bisexual OEF/OIF Veterans^418^ | Mental health, Utilization | 335 | Utilization | Utilization (medical, mental health) | No | 0
Mattocks, 2013: Sexual victimization, health status, and VA healthcare utilization among lesbian and bisexual OEF/OIF Veterans^418^ | Mental health, Utilization | 335 | Health Outcome | Diagnosed mental health condition, patient ratings of mental health status | Mixed/Unclear | 0