# APPENDIX P HEALTH DISPARITIES BY ERA OF MILITARY SERVICE

Evidence Map Health Disparities in Veterans by Era of Military Service

Legend: The bubble plot shows the number of studies identified (y-axis) that provided evidence of no disparity, mixed or unclear findings, or a disparity (x-axis) for each outcome category (utilization, quality, patient health outcomes). Quality of care studies included processes of care, intermediate outcomes, and patient evaluations of care. Bubble size represents the mean confidence score, with a range of -1 to 4.

Table Health Disparities in Veterans by Era of Military Service

Author, Year: Title | Clinical area | Total N | Category | Outcomes | Disparity | Confidence
Belsher, 2012: Compensation and treatment: disability benefits and outcomes of U.S. Veterans receiving residential PTSD treatment^404^ | Mental health (PTSD) | 786 | Utilization | Residential length of stay for PTSD | Yes | 0
Belsher, 2012: Compensation and treatment: disability benefits and outcomes of U.S. Veterans receiving residential PTSD treatment^404^ | Mental health (PTSD) | 786 | Health Outcome | PTSD and depression symptoms | Yes | 0
Berke, 2010: Comparison of satisfaction with current prosthetic care in Veterans and servicemembers from Vietnam and OIF/OEF conflicts with major traumatic limb loss^405^ | Prosthetic care | 581 | Quality | Patient satisfaction with care and current prosthesis | No | 0
Doran, 2013: What drives frequent emergency department use in an integrated health system? National data from the Veterans Health Administration^275^ | Utilization (ED) | 5531379 | Utilization | VHA ED utilization | No | 3
El-Serag, 2014: Racial differences in the progression to cirrhosis and hepatocellular carcinoma in HCV-infected Veterans^121^ | HCV, cancer (liver) | 149407 | Health Outcome | Risk of cirrhosis or hepatocellular cancer | Yes | 3
Fontana, 2010: Female Veterans of Iraq and Afghanistan seeking care from VA specialized PTSD programs: Comparison with male Veterans and female war zone Veterans of previous eras^281^ | Mental health (PTSD) | 1738 | Health Outcome | Diagnosis of PTSD, alcohol abuse/depression, drug abuse/depression, anxiety disorder, mood disorder, bipolar disorder, schizophrenia, medical problem; service connection for PTSD, other psychiatric disorder, or medical disorder; psychiatric disability and medical disability | Mixed/ Unclear | 1
Hawkins, 2010: Recognition and management of alcohol misuse in OEF/OIF and other Veterans in the VA: a cross-sectional study^292^ | Mental health (substance use disorder) | 12092 | Quality | Treatment for alcohol misuse | No | 2
Hawkins, 2010: Recognition and management of alcohol misuse in OEF/OIF and other Veterans in the VA: a cross-sectional study^292^ | Mental health (substance use disorder) | 12092 | Health Outcome | Prevalence of alcohol misuse | Mixed/ Unclear | 2
Hawkins, 2012: Prevalence, predictors, and service utilization of patients with recurrent use of Veterans Affairs substance use disorder specialty care^293^ | Mental health (substance use disorder) | 1640 | Utilization | Utilization of substance use disorder specialty services following an index encounter | No | 0
Hermes, 2012: Recent trends in the treatment of posttraumatic stress disorder and other mental disorders in the VHA^406^ | Mental health (PTSD) | 1100564 | Utilization | Utilization (mental health visits) | Mixed/ Unclear | 2
Jain, 2012: Do Veterans with posttraumatic stress disorder receive first-line pharmacotherapy? Results from the Longitudinal Veterans Health Survey^407^ | Mental health (PTSD) | 972 | Quality | Initiating and receiving a therapeutic trial of an SSRI/SNRI | Yes | 1
Lund, 2013: Patient and Facility Characteristics Associated with Benzodiazepine Prescribing for Veterans with PTSD^300^ | Mental health (PTSD) | 495309 | Quality | Benzodiazepine prescription | Yes | 3
Mohanty, 2015: Chronic Multisymptom Illness among Female Veterans Deployed to Iraq and Afghanistan^408^ | Chronic disease | 78435 | Quality | Diagnosis of a chronic multisymptom illness | Yes | 3
Paddock, 2013: The quality of mental health care for Veterans of Operation Enduring Freedom/Operation Iraqi Freedom^409^ | Mental health (substance use disorder) | 836699 | Utilization | Utilization performance indicators | Mixed/ Unclear | 3
Paddock, 2013: The quality of mental health care for Veterans of Operation Enduring Freedom/Operation Iraqi Freedom^409^ | Mental health (substance use disorder) | 836699 | Quality | Processes of care | No | 3
Tsai, 2014: The effects of race and other socioeconomic factors on health service use among American military Veterans^235^ | Utilization | 19270 | Utilization | Utilization (outpatient, mental health) | Mixed/ Unclear | 2
Washington, 2013: Women Veterans' healthcare delivery preferences and use by military service era: findings from the National Survey of Women Veterans^410^ | Women's health, Utilization | 3607 | Utilization | Utilization: any, VA, women's health, primary care, mental health, specialty care, regular source of care | Mixed/ Unclear | 0
Washington, 2016: Military generation and its relationship to mortality in women Veterans in the Women's Health Initiative^411^ | Mortality | 3719 | Health Outcome | All-cause mortality (baseline-2010, max of 17 years) | Mixed/ Unclear | 2