# APPENDIX O HEALTH DISPARITIES IN VETERANS WITH DISABILITIES

Evidence Map Health Disparities in Veterans with Disabilities

Legend: The bubble plot shows the number of studies identified (y-axis) that provided evidence of no disparity, mixed or unclear findings, or a disparity (x-axis) for each outcome category (utilization, quality, patient health outcomes). Quality of care studies included processes of care, intermediate outcomes, and patient evaluations of care. Bubble size represents the mean confidence score, with a range of -1 to 4.

Table Health Disparities in Veterans with Disabilities

Author, Year: Title | Clinical area | Total N | Category | Outcomes | Disparity | Confidence
Burnett-Zeigler, 2011: Perceptions of quality of health care among Veterans with psychiatric disorders^267^ | Mental health, Quality of Care | 55578 | Quality | Perception of quality of care | No | 1
Carey, 2008: Use of VA and Medicare services by dually eligible Veterans with psychiatric problems^367^ | Mental health (Dual Diagnosis) | 264619 | Utilization | Total expenditures: acute and non-acute inpatient and outpatient utilization (VA and Medicare) and pharmacy utilization (VA only) | Yes | 3
Doran, 2013: What drives frequent emergency department use in an integrated health system? National data from the Veterans Health Administration^275^ | Utilization (ED) | 5531379 | Utilization | VHA ED utilization | No | 3
Duffy, 2012: Risk of smoking and receipt of cessation services among Veterans with mental disorders^111^ | Smoking cessation | 224193 | Quality | Physician advised quitting, physician recommended medication, physician discussed quitting methods | Mixed/ Unclear | 3
Duggal, 2010: Comparison of outpatient health care utilization among returning women and men Veterans from Afghanistan and Iraq^276^ | Utilization (outpatient) | 1620 | Utilization | Outpatient utilization (basic, specialty, ancillary) | No | 1
Elhai, 2008: Outpatient medical and mental healthcare utilization models among military Veterans: results from the 2001 National Survey of Veterans^33^ | Utilization (outpatient medical and mental health) | 20048 | Utilization | Number of outpatient healthcare visits (VA and non-VA) and receipt of mental health services | Yes | 2
Finegan, 2010: Trends and geographic variation of potentially avoidable hospitalizations in the Veterans Health-Care System^369^ | Access (ambulatory care-sensitive condition hospitalizations) | NR (100,000+) | Utilization | Ambulatory care-sensitive condition (ACSC) hospitalizations | Yes | 3
Ho, 2006: The association between processes, structures and outcomes of secondary prevention care among VA ischemic heart disease patients^355^ | Cardiovascular health | 14114 | Quality | Concordance with LDL-C and blood pressure guidelines | No | 2
Hundt, 2014: Predisposing, enabling, and need factors as predictors of low and high psychotherapy utilization in Veterans^295^ | Mental health, Utilization | 130331 | Utilization | Psychotherapy utilization | Yes | 3
Irmiter, 2007: Reinstitutionalization following psychiatric discharge among VA patients with serious mental illness: a national longitudinal study^158^ | Mental health (serious mental illness) | 35527 | Health Outcome | Time to reinstitutionalization/rehospitalization | Yes | 1
Littman, 2012: Preventive services in Veterans in relation to disability^403^ | Preventive care/screening | 72855 | Quality | Influenza, pneumococcal vaccinations; fecal occult blood test; lower gastrointestinal endoscopy; cholesterol screening; weight management counseling; HIV test; mammography; pap smear | Mixed/ Unclear | 2
Lynch, 2015: Geographic and racial/ethnic variations in patterns of multimorbidity burden in patients with type 2 diabetes^185^ | Diabetes | 892223 | Health Outcome | Multimorbidity | Yes | 3
Mattocks, 2015: Infertility care among OEF/OIF/OND women Veterans in the Department of Veterans Affairs^187^ | Women's health (reproductive health) | 1323 | Quality | Received an infertility assessment | No | 0
Sambamoorthi, 2012: Decomposing gender differences in low-density lipoprotein cholesterol among Veterans with or at risk for cardiovascular illness^219^ | Cardiovascular (lipid management) | 527568 | Quality | LDL-C greater than or equal to 130 | No | 3
Tseng, 2006: Diabetes care among Veteran women with disability^236^ | Diabetes | 5110 | Quality | Hemoglobin A1c level and LDL-C screening | No | 1
Washington, 2009: Women Veterans ambulatory care use project, phase II^242^ | Women's health | 2174 | Utilization | Utilization of VA women's health services | Yes | 1