# APPENDIX N HEALTH DISPARITIES ACCORDING TO SOCIOECONOMIC STATUS

Evidence Map Health Disparities in Veterans According to Socioeconomic Status

Legend: The bubble plot shows the number of studies identified (y-axis) that provided evidence of no disparity, mixed or unclear findings, or a disparity (x-axis) for each outcome category (utilization, quality, patient health outcomes). Quality of care studies included processes of care, intermediate outcomes, and patient evaluations of care. Bubble size represents the mean confidence score, with a range of -1 to 4.

Table Health Disparities in Veterans According to Socioeconomic Status

Author, Year: Title | Clinical area | Total N | Category | Outcomes | Disparity | Confidence
Arozullah, 2007: The impact of health literacy on racial differences in cancer stage at presentation^398^ | Cancer | 296 | Health Outcome | Advanced stage cancer at presentation | Yes | 1
Bean-Mayberry, 2009: Does sex influence immunization status for influenza and pneumonia in older Veterans^81^ | Preventive care (immunization status), older adults | 48424 | Quality | Receipt of influenza immunization in the prior influenza season and receipt of pneumonia immunization ever | Mixed/ Unclear | 2
Borrero, 2012: Contraceptive care in the VA health care system^84^ | Women's health (contraceptive care) | 103950 | Quality | Receipt and type of contraception | No | 3
Burnett-Zeigler, 2011: Perceptions of quality of health care among Veterans with psychiatric disorders^267^ | Mental health | 55578 | Quality | Perception of quality of care | Mixed/ Unclear | 1
Cecere, 2012: Adherence to long-acting inhaled therapies among patients with chronic obstructive pulmonary disease (COPD)^96^ | Chronic obstructive pulmonary disease | 376 | Quality | Medication adherence | Mixed/ Unclear | 2
Elhai, 2008: Outpatient medical and mental healthcare utilization models among military Veterans: results from the 2001 National Survey of Veterans^33^ | Utilization (outpatient medical and mental health) | 20048 | Utilization | Number of outpatient healthcare visits (VA and non-VA) and receipt of mental health services | Mixed/ unclear | 2
Finegan, 2010: Trends and geographic variation of potentially avoidable hospitalizations in the Veterans Health-Care System^369^ | Access (ambulatory care-sensitive condition hospitalizations) | NR (100,000+) | Utilization | Ambulatory care-sensitive condition (ACSC) hospitalizations | Yes | 3
Gabrielian, 2014: VA health service utilization for homeless and low-income Veterans: a spotlight on the VA Supportive Housing (VASH) program in greater Los Angeles^399^ | Utilization | 62459 | Utilization | Differences in service utilization (primary care, hospital, mental health, specialty) | Yes | 1
Gordon, 2014: Examining patients' trust in physicians and the VA healthcare system in a prospective cohort followed for six-months after an exacerbation of heart failure^134^ | Cardiovascular (heart failure) | 159 | Quality | Trust in physician, trust in VHA | Yes | 2
Haskell, 2009: Pain among Veterans of Operations Enduring Freedom and Iraqi Freedom: Do women and men differ?^142^ | Pain | 153212 | Health Outcome | Pain: reported any pain, reported moderate-severe pain, reported persistent pain | No | 3
Higgins, 2014: Persistent pain and comorbidity among Operation Enduring Freedom/Operation Iraqi Freedom/Operation New Dawn Veterans^149^ | Pain (chronic) | 5242 | Health Outcome | Persistent pain (either self-rated scale, ICD-9 pain diagnosis, pain clinic visit, or opioid prescription) | No | 1
Jackson, 2008: Racial/ethnic and educational-level differences in diabetes care experiences in primary care^258^ | Diabetes | 189 | Quality | Patient with diabetes perceptions of alignment with chronic care model (Patient Assessment of Chronic Illness Care) | No | 0
Kazerooni, 2014: Predictors of adherence to hormonal contraceptives in a female Veteran population^165^ | Women's health (hormonal contraceptives) | 805 | Health Outcome | Adherence to hormonal contraceptive medication (medication possession ratio >.9) | Yes | 0
Kilbourne, 2006: Quality of care for substance use disorders in patients with serious mental illness^167^ | Mental health (serious mental illness) | 8083 | Quality | Identification of substance use disorders, initiation of treatment, engagement in treatment | Mixed/ Unclear | 1
Kimerling, 2011: Military sexual trauma and patient perceptions of Veteran Health Administration health care quality^170^ | Mental health (sexual trauma) | 164632 | Quality | Patient satisfaction with VHA outpatient care | Mixed/ Unclear | 2
Knight, 2007: Education predicts quality of life among men with prostate cancer cared for in the Department of Veterans Affairs: a longitudinal quality of life analysis from CaPSURE^400^ | Cancer (prostate) | 248 | Health Outcome | Self-reported health-related QOL, SF-36, UCLA Prostate Cancer Index (PCI) at baseline and posttreatment (6 or 12 months) | Yes | 1
Lehavot, 2015: Posttraumatic stress disorder symptom severity and socioeconomic factors associated with Veterans Health Administration use among women Veterans^356^ | Mental health, Utilization | 617 | Utilization | Utilization of VA healthcare within past year | Yes | 0
Mackenzie, 2010: Impact of rural residence on survival of male Veterans affairs patients after age 65^186^ | Mortality (65+) | 372463 | Health Outcome | Mortality | Yes | 3
Mattocks, 2015: Infertility care among OEF/OIF/OND women Veterans in the Department of Veterans Affairs^187^ | Women's health (Reproductive health) | 1323 | Quality | Received an infertility assessment | No | 0
Mehta, 2010: Racial disparities in prescriptions for cardioprotective drugs and cardiac outcomes in Veterans Affairs Hospitals^190^ | Cardiovascular disease | 474565 | Quality | Prescriptions for cardioprotective drugs (aspirin, beta-blocker, statin, angiotensin-converting enzyme inhibitor) | Mixed/ Unclear | 3
Mehta, 2010: Racial disparities in prescriptions for cardioprotective drugs and cardiac outcomes in Veterans Affairs Hospitals^190^ | Cardiovascular disease | 474565 | Health Outcome | Angina and AMI | Yes | 3
Moore, 2015: Racial, income, and marital status disparities in hospital readmissions within a Veterans-integrated health care network^194^ | Inpatient/acute care | 8718 | Utilization | Number of hospital readmissions | No | 1
Nelson, 2011: Neighborhood environment and health status and mortality among Veterans^401^ | Physical and mental health status | 15889 | Health Outcome | Physical and mental health status, mortality | Yes | 2
Partin, 2010: The interrelationships between and contributions of background, cognitive, and environmental factors to colorectal cancer screening adherence^358^ | Cancer (colorectal) | 2416 | Quality | Colorectal cancer screening adherence | No | 1
Rawaf, 2007: Exploring racial and sociodemographic trends in physician behavior, physician trust and their association with blood pressure control^209^ | Cardiovascular disease | 793 | Quality | Blood pressure control | No | 2
Sajatovic, 2006: Self-reported medication treatment adherence among Veterans with bipolar disorder^304^ | Mental health (bipolar) | 184 | Quality | Self-report of medication adherence | No | 0
Spoont, 2015: Are there racial/ethnic disparities in VA PTSD treatment retention?^231^ | Mental health (PTSD) | 6788 | Quality | PTSD treatment retention | No | 2
Taber, 2016: Overall graft loss versus death-censored graft loss: unmasking the magnitude of racial disparities in outcomes among US kidney transplant recipients^232^ | Renal | 4918 | Health Outcome | Overall graft loss, death, and death-censored graft loss | No | 1
Tsai, 2014: The effects of race and other socioeconomic factors on health service use among American military Veterans^235^ | Utilization | 19270 | Utilization | Health service use | No | 2
Tseng, 2007: The association between mental health functioning and nontraumatic lower extremity amputations in Veterans with diabetes^237^ | Diabetes | 114890 | Health Outcome | Major and minor non-traumatic lower extremity amputations | Mixed/ Unclear | 3
Washington, 2011: Access to care for women Veterans: delayed healthcare and unmet need^362^ | Access | 3608 | Utilization | Delays in obtaining needed healthcare and instances of going without needed care in the prior 12 months | Mixed/ unclear | 0
Widome, 2015: Socioeconomic disparities in sleep duration among Veterans of the US wars in Iraq and Afghanistan^402^ | Sleep | 867 | Quality | Sleep duration | Yes | 0