# APPENDIX M HEALTH DISPARITIES ACCORDING TO RURAL RESIDENCE OR DISTANCE FROM VA MEDICAL CENTER

Evidence Map Health Disparities in Veterans According to Rural Residence or Distance from VA Medical Center

Legend: The bubble plot shows the number of studies identified (y-axis) that provided evidence of no disparity, mixed or unclear findings, or a disparity (x-axis) for each outcome category (utilization, quality, patient health outcomes). Quality of care studies included processes of care, intermediate outcomes, and patient evaluations of care. Bubble size represents the mean confidence score, with a range of -1 to 4.

Table Health Disparities in Veterans According to Rural Residence or Distance from VA Medical Center

Author, Year: Title | Population | Clinical area | Total N | Category | Outcomes | Disparity | Confidence
Abrams, 2010: Mortality and revascularization following admission for acute myocardial infarction: implication for rural Veterans^363^ | Rural residence | Cardiovascular (Acute MI) | 15608 | Health Outcome | 30-day mortality | No | 2
Bailey, 2012: The impact of living in rural and urban areas: vitamin D and medical costs in Veterans^364^ | Rural residence | Vitamin D levels | 9396 | Utilization | Utilization and medical costs | Mixed/ Unclear | 1
Bailey, 2012: The impact of living in rural and urban areas: vitamin D and medical costs in Veterans^364^ | Rural residence | Vitamin D levels | 9396 | Quality | Vitamin D levels | Yes | 1
Banerjea, 2009: Mental illness and substance use disorders among women Veterans with diabetes^79^ | Rural residence | Diabetes, Mental health | 16023 | Health Outcome | Serious mental illness and/or substance use disorder diagnoses | No | 2
Bouldin, 2015: Chronic lower limb wound outcomes among rural and urban Veterans^365^ | Rural residence | Wound care (Chronic lower limb wounds) | 320 | Utilization | Healthcare utilization for chronic lower limb wounds | Mixed/ Unclear | 1
Bouldin, 2015: Chronic lower limb wound outcomes among rural and urban Veterans^365^ | Rural residence | Wound care (Chronic lower limb wounds) | 320 | Health Outcome | Amputations; mortality | Mixed/ Unclear | 1
Brooks, 2014: Rural women Veterans demographic report: defining VA users' health and health care access in rural areas^366^ | Rural residence | Women's health (Veterans seeking outpatient visits for primary care, mental health care, and women's specific services) | 327785 | Utilization | Mental health, outpatient, and women's health tilization | Yes | 3
Brooks, 2014: Rural women Veterans demographic report: defining VA users' health and health care access in rural areas^366^ | Rural residence | Women's health (Veterans seeking outpatient visits for primary care, mental health care, and women's specific services) | 327785 | Health Outcome | Medical or mental health diagnosis | No | 2
Carey, 2008: Use of VA and Medicare services by dually eligible Veterans with psychiatric problems^367^ | Distance from VAMC | Mental health (Dual Diagnosis) | 264619 | Utilization | Total expenditures: acute and non-acute inpatient and outpatient utilization (VA and Medicare) and pharmacy utilization (VA only) | Yes | 3
Cully, 2010: Use of psychotherapy by rural and urban Veterans^368^ | Rural residence | Mental health care | 214791 | Utilization | Psychotherapy initiation, delay from diagnosis, and dose (number of sessions) | Yes | 3
Doran, 2013: What drives frequent emergency department use in an integrated health system? National data from the Veterans Health Administration^275^ | Rural residence | Utilization (ED) | 5531379 | Utilization | VHA ED utilization | Mixed/ Unclear | 3
Duffy, 2012: Risk of smoking and receipt of cessation services among Veterans with mental disorders^111^ | Rural residence | Smoking cessation | 224193 | Quality | Physician advised quitting, physician recommended medication, physician discussed quitting methods | Mixed/ Unclear | 3
Egede, 2011: Regional, geographic, and ethnic differences in medication adherence among adults with type 2 diabetes^114^ | Rural residence | Diabetes | 690968 | Quality | Medication adherence (MPR-med possession ratio) | No | 3
Egede, 2011: Regional, geographic, and racial/ethnic variation in glycemic control in a national sample of Veterans with diabetes^115^ | Rural residence | Diabetes | 690698 | Quality | Hemoglobin A1c level, poor control of hemoglobin A1c level (<80%) | No | 3
Egede, 2013: Differential impact of longitudinal medication non-adherence on mortality by race/ethnicity among Veterans with diabetes^117^ | Rural residence | Diabetes | 629563 | Health Outcome | Medication non-adherence associated mortality | Mixed/ Unclear | 3
Elhai, 2008: Outpatient medical and mental healthcare utilization models among military Veterans: results from the 2001 National Survey of Veterans^33^ | Rural residence | Utilization (outpatient medical and mental health) | 20048 | Utilization | Number of outpatient healthcare visits (VA and non-VA) and receipt of mental health services | Mixed/ Unclear | 2
Finegan, 2010: Trends and geographic variation of potentially avoidable hospitalizations in the Veterans Health-Care System^369^ | Rural residence | Access (ambulatory care-sensitive condition hospitalizations) | NR (100,000+) | Utilization | Ambulatory care-sensitive condition (ACSC) hospitalizations | Yes | 3
Finegan, 2010: Trends and geographic variation of potentially avoidable hospitalizations in the Veterans Health-Care System^369^ | Distance from VAMC | Access (ambulatory care-sensitive condition hospitalizations) | NR (100,000+) | Utilization | Ambulatory care-sensitive condition (ACSC) hospitalizations | Yes | 3
Friedman, 2015: Travel time and attrition from VHA care among women Veterans: how far is too far?^370^ | Distance from VAMC | Women's health | 266301 | Quality | An “attriter” did not return for VHA care during the 2nd through 3rd years after her first 2009 visit (T0). Drive time (log minutes) was between the patient's residence and her regular source of VHA care. “New” patients had no VHA visits within 3 years before T0. | Yes | 3
Goldberg, 2014: Association of distance from a transplant center with access to waitlist placement, receipt of liver transplantation, and survival among US Veterans^371^ | Distance from VAMC | Transplantation (liver) | 50637 | Quality | Waitlisted for liver transplantation | Yes | 2
Goldberg, 2014: Association of distance from a transplant center with access to waitlist placement, receipt of liver transplantation, and survival among US Veterans^371^ | Distance from VAMC | Transplantation (liver) | 50637 | Health Outcome | Receiving a liver transplant, mortality | Yes | 2
Grubaugh, 2009: Equity in Veterans Affairs disability claims adjudication in a national sample of Veterans^139^ | Rural residence | Disability | 20048 | Quality | Disability benefits | No | 2
Ho, 2006: The association between processes, structures and outcomes of secondary prevention care among VA ischemic heart disease patients^355^ | Distance from VAMC | Cardiovascular health | 14114 | Quality | Concordance with LDL-C and blood pressure guidelines | No | 2
Hudson, 2014: Effect of rural residence on use of VHA mental health care among OEF/OIF Veterans^372^ | Rural residence | Mental health | 4782 | Utilization | Utilization of mental health treatments | Yes | 1
Hudson, 2014: Effect of rural residence on use of VHA mental health care among OEF/OIF Veterans^372^ | Rural residence | Mental health | 4782 | Health Outcome | PTSD diagnosis | Yes | 1
Hundt, 2014: Predisposing, enabling, and need factors as predictors of low and high psychotherapy utilization in Veterans^295^ | Distance from VAMC | Mental health, Utilization | 130331 | Utilization | Psychotherapy utilization | Yes | 3
Lund, 2013: Patient and Facility Characteristics Associated with Benzodiazepine Prescribing for Veterans with PTSD^300^ | Rural residence | Mental health (PTSD) | 495309 | Quality | Benzodiazepine prescription | Yes | 3
Lund, 2013: Regional differences in prescribing quality among elder Veterans and the impact of rural residence^373^ | Rural residence | Geriatrics, Prescribing | 1549824 | Quality | Inappropriate prescribing | Mixed/ Unclear | 3
Lynch, 2011: Disparities in diabetes self-management and quality of care in rural versus urban Veterans^374^ | Rural residence | Diabetes | 10472 | Quality | Diabetes self-management behaviors (lifestyle and self-monitoring) and quality of care indicators (provider visits, laboratory monitoring and preventive measures) | No | 2
Maciejewski, 2007: Utilization and expenditures of Veterans obtaining primary care in community clinics and VA medical centers: an observational cohort study^375^ | Distance from VAMC | Utilization (Primary care) | 61144 | Utilization | Primary care utilization | Mixed/ Unclear | 2
Mackenzie, 2010: Impact of rural residence on survival of male Veterans affairs patients after age 65^186^ | Rural residence | Mortality (65+) | 372463 | Health Outcome | Mortality | Mixed/ Unclear | 3
McCarthy, 2007: Veterans Affairs Health System and mental health treatment retention among patients with serious mental illness: evaluating accessibility and availability barriers^376^ | Distance from VAMC | Mental health (serious mental illness) | 156631 | Utilization | VA service utilization, mental health utilization | Yes | 3
McCarthy, 2012: Suicide among patients in the Veterans Affairs health system: rural-urban differences in rates, risks, and methods^377^ | Distance from VAMC | Mental health (Suicidality) | 11139863 | Health Outcome | Suicide | Mixed/ Unclear | 3
Mohamed, 2009: VA intensive mental health case management in urban and rural areas: Veteran characteristics and service delivery^378^ | Rural residence | Mental health (severe and persistent) | 5221 | Health Outcome | GAF, QOL, activities of daily living, symptom severity | No | 0
Morden, 2010: Quality of care for cardiometabolic disease: associations with mental disorder and rurality^342^ | Rural residence | Cardiovascular (hypertension) | 23780 | Quality | Blood pressure control, poor blood pressure | No | 2
Nash, 2011: Trauma and substance use disorders in rural and urban Veterans^379^ | Rural residence | Mental health (PTSD) | 60 | Health Outcome | PTSD symptoms | No | 0
Ohl, 2010: Rural residence is associated with delayed care entry and increased mortality among Veterans with human immunodeficiency virus infection^380^ | Rural residence | HIV | 8489 | Utilization | Initiated treatment | No | 1
Ohl, 2010: Rural residence is associated with delayed care entry and increased mortality among Veterans with human immunodeficiency virus infection^380^ | Rural residence | HIV | 8489 | Health Outcome | Hepattis C, mortality | Mixed/ Unclear | 1
Ohl, 2013: Rural residence and adoption of a novel HIV therapy in a national, equal-access healthcare system^381^ | Rural residence | HIV | 1222 | Quality | Initiation of new HIV therapy (raltegravir) for eligible patients | Yes | 1
Ohl, 2014: Geographic access and use of infectious diseases specialty and general primary care services by Veterans with HIV infection: Implications for telehealth and shared care programs^382^ | Rural residence | HIV | 23639 | Utilization | Utilization of infectious disease clinics (HIV patients) | No | 2
Ohl, 2014: Geographic access and use of infectious diseases specialty and general primary care services by Veterans with HIV infection: Implications for telehealth and shared care programs^382^ | Distance from care | HIV | 23639 | Utilization | Utilization of infectious disease clinics (HIV patients) | Yes | 2
Patterson, 2014: Rural access to clinical pharmacy services^383^ | Rural residence | Clinical pharmacy services | 3040635 | Utilization | Utilization of clinical pharmacy services | No | 3
Pfeiffer, 2011: Impact of distance and facility of initial diagnosis on depression treatment^384^ | Distance from VAMC | Mental health (Depression) | 132329 | Utilization | Psychotherapy and pharmaceutical treatment of depression | Yes | 3
Phipps, 2014: Rural-urban differences in inpatient quality of care in US Veterans with ischemic stroke^385^ | Rural residence | Cardiovascular (Stroke) | 3889 | Quality | Ischemic stroke treatment | Mixed/ Unclear | 1
Pugh, 2008: Potentially inappropriate prescribing for the elderly: effects of geriatric care at the patient and health care system level^206^ | Rural residence | Geriatrics, Prescribing | 850154 | Quality | Potentially inappropriate prescribing in the elderly | No | 3
Ripley, 2015: How does geographic access affect in-hospital mortality for Veterans with acute ischemic stroke?^386^ | Distance from VAMC | Cardiovascular (Stroke) | 10430 | Health Outcome | In-hospital mortality | Yes | 3
Rongey, 2013: Impact of rural residence and health system structure on quality of liver care^387^ | Rural residence | HCV | 151965 | Utilization | Utilization of HCV specialty care | Yes | 3
Rongey, 2013: Impact of rural residence and health system structure on quality of liver care^387^ | Rural residence | HCV | 151965 | Quality | HCV quality indicators | Mixed/ Unclear | 3
Sambamoorthi, 2012: Decomposing gender differences in low-density lipoprotein cholesterol among Veterans with or at risk for cardiovascular illness^219^ | Rural residence | Cardiovascular (lipid management) | 527568 | Quality | LDL-C greater than or equal to 130 | Mixed/ Unclear | 3
Sarangarm, 2010: Post-endovascular aneurysm repair patient outcomes and follow-up are not adversely impacted by long travel distance to tertiary vascular surgery centers^388^ | Distance from VAMC | Surgery follow-up | 126 | Utilization | Post-surgery follow-up | No | 0
Sarangarm, 2010: Post-endovascular aneurysm repair patient outcomes and follow-up are not adversely impacted by long travel distance to tertiary vascular surgery centers^388^ | Distance from VAMC | Surgery follow-up | 126 | Health Outcome | Post-surgery outcomes | No | 0
Skolarus, 2013: Quality of prostate cancer care among rural men in the Veterans Health Administration^389^ | Rural residence | Cancer (prostate) | 11333 | Utilization | Utilization of facilities with comprehensive cancer resources | Yes | 1
Skolarus, 2013: Quality of prostate cancer care among rural men in the Veterans Health Administration^389^ | Rural residence | Cancer (prostate) | 11333 | Quality | Prostate cancer care | No | 1
Thorpe, 2010: Rural-urban differences in preventable hospitalizations among community-dwelling Veterans with dementia^390^ | Rural residence | Dementia | 1186 | Utilization | ACSH (ambulatory care-sensitive hospitalizations) | Yes | 1
Turner, 2013: Access to multiple sclerosis specialty care^391^ | Rural residence | Pain (Multiple sclerosis) | 14723 | Utilization | Specialty care visit, receipt of medical services | Yes | 2
Turner, 2013: Access to multiple sclerosis specialty care^391^ | Distance from VAMC | Pain (Multiple sclerosis) | 14723 | Utilization | Specialty care visit, receipt of medical services | Yes | 2
Wallace, 2006: Rural and Urban Disparities in Health-Related Quality of Life among Veterans with Psychiatric Disorders^392^ | Rural residence | Physical and mental health status | 748216 | Health Outcome | Health-related QOL scores (physical and mental) health component summaries | Yes | 3
Wallace, 2010: A cross-sectional, multi-year examination of rural and urban Veterans Administration users: 2002-2006^393^ | Rural residence | Physical and mental health status | Between 263,000-420,000/year | Health Outcome | Physical health status, mental health status | Mixed/ Unclear | 3
Wallace, 2010: A longitudinal analysis of rural and urban Veterans' health-related quality of life^394^ | Rural residence | Quality of life, health-related | 163709 | Health Outcome | Health-related QOL scores (physical and mental) health component summaries | Mixed/ Unclear | 3
Washington, 2009: Women Veterans ambulatory care use project, phase II^242^ | Distance from VAMC | Women's health | 2174 | Utilization | Utilization of VA women's health services | Yes | 1
Weeks, 2006: Rural-urban disparities in health-related quality of life within disease categories of Veterans^395^ | Rural residence | Quality of life, health-related | 570512 | Health Outcome | Health-related QOL scores (physical and mental) health component summaries | Yes | 3
West, 2008: Rural Veterans and access to high-quality care for high-risk surgeries^396^ | Rural residence | Surgery (Open heart) | NR (24K+) | Utilization | Open heart surgery at higher- or lower-performing (mortality) hospital | Mixed/ Unclear | 2
Whealin, 2014: Deployment-related sequelae and treatment utilization in rural and urban war Veterans in Hawaii^397^ | Rural residence | Mental health | 233 | Utilization | Utilization of mental health services | No | 0
Whealin, 2014: Deployment-related sequelae and treatment utilization in rural and urban war Veterans in Hawaii^397^ | Rural residence | Mental health | 233 | Health Outcome | Deployment-related health issues | Yes | 0

Note: Some studies examined outcomes by both a measure of rurality and by distance from a VA medical center.