# APPENDIX L HEALTH DISPARITIES ACCORDING TO AGE

Evidence Map Health Disparities in Veterans According to Age

Legend: The bubble plot shows the number of studies identified (y-axis) that provided evidence of no disparity, mixed or unclear findings, or a disparity (x-axis) for each outcome category (utilization, quality, patient health outcomes). Quality of care studies included processes of care, intermediate outcomes, and patient evaluations of care. Bubble size represents the mean confidence score, with a range of -1 to 4.

Table Health Disparities in Veterans According to Age

Author, Year: Title | Clinical area | Total N | Category | Outcomes | Disparity | Confidence
Aliaga, 2007: Mental health encounters and diagnoses following deployment to Iraq and/or Afghanistan, US Armed Forces, 2001–2006^263^ | Mental health diagnoses | 865674 | Health Outcome | PTSD diagnosis | Younger Adults | 2
Banerjea, 2007: Chronic illness with complexities: Mental illness and substance use among Veteran clinic users with diabetes^78^ | Diabetes, co-occurring substance use and mental health disorders in patients with diabetes | 485893 | Health Outcome | Mental health status, substance use disorder, combined mental health and substance use disorder, access to care, and diabetes-related health complications | Older Adults | 3
Banerjea, 2009: Mental illness and substance use disorders among women Veterans with diabetes^79^ | Mental health in women with diabetes | 16368 | Health Outcome | Serious mental illness and/or substance use disorder diagnoses | Younger Adults | 2
Bierman, 2007: Sex differences in inappropriate prescribing among elderly Veterans^82^ | Geriatrics, Prescribing | 965756 | Quality | Zhan criteria for inappropriate prescribing for older adults | Older Adults | 2
Boehmer, 2016: Dental care in an equal access system valuing equity: Are there racial disparities?^83^ | Dental | 71315 | Quality | Receipt of root canal vs extraction | Older Adults | 0
Buchanan, 2014: The quality of care provided to patients with varices in the department of Veterans Affairs^88^ | Varices-related care | 550 | Quality | Rate of meeting specified quality indicators for varices-related care | Older Adults | 1
Burnett-Zeigler, 2011: Perceptions of quality of health care among Veterans with psychiatric disorders^267^ | Mental health, Quality of Care | 55578 | Quality | Perception of quality of care | Younger Adults | 1
Butt, 2006: Rates and predictors of hepatitis C virus treatment in HCV-HIV-coinfected subjects^93^ | HCV, HIV | 6502 | Quality | Prescribed treatment for HCV | Older Adults | 1
Cecere, 2012: Adherence to long-acting inhaled therapies among patients with chronic obstructive pulmonary disease (COPD)^96^ | Chronic obstructive pulmonary disease | 376 | Quality | Medication adherence | Younger Adults | 2
Chumbler, 2012: Does inpatient quality of care differ by age among US Veterans with ischemic stroke?^351^ | Cardiovascular (Stroke) | 3939 | Quality | Quality indicators: dysphagia screening, NIHSS completed, thrombolysis given, antithrombotic therapy, HD2, DVT prophylaxis, early ambulation, fall risk assessment, pressure ulcer risk assessment, rehabilitation consultation/FIM, antithrombotic therapy, discharge, atrial fibrillation management, smoking cessation counseling, stroke education | Mixed/ Unclear | 1
Chumbler, 2013: Postdischarge quality of care: do age disparities exist among Department of Veterans Affairs ischemic stroke patients?^352^ | Cardiovascular (Stroke) | 3196 | Quality | Post-stroke care quality indicators | None Found | 1
Cone, 2011: Demographic determinants of response to statin medications^101^ | Cardiovascular (coronary artery disease) | 5191 | Quality | Achieving goal of LDL-C <100 | Mixed/ Unclear | 0
Copeland, 2008: Treatment adherence and illness insight in Veterans with bipolar disorder^102^ | Mental health | 435 | Quality | Medication adherence (Morisky scale, no missed doses) | Younger Adults | 0
Curran, 2009: Individual and program predictors of attrition from VA substance use treatment^105^ | Mental health (substance use disorder) | 8064 | Quality | Rates of attrition | Older Adults | 1
Desai, 2006: Case-finding for depression among medical outpatients in the Veterans Health Administration^274^ | Mental health (Depression) | 21489 | Quality | Depression screening, screening positive, follow-up evaluation, and subsequent diagnosis | Younger Adults | 2
Desai, 2006: Case-finding for depression among medical outpatients in the Veterans Health Administration^274^ | Mental health (Depression) | 21489 | Health Outcome | Screening positive | Younger Adults | 2
DiNapoli, 2015: Age as a predictive factor of mental health service use among adults with depression and/or anxiety disorder receiving care through the Veterans Health Administration^353^ | Mental health | 583692 | Utilization | Mental health service utilization | Older Adults | 3
Doran, 2013: What drives frequent emergency department use in an integrated health system? National data from the Veterans Health Administration^275^ | Utilization (ED) | 5531379 | Utilization | VHA ED utilization | None Found | 3
Duffy, 2012: Risk of smoking and receipt of cessation services among Veterans with mental disorders^111^ | Smoking cessation | 224193 | Quality | Physician advised quitting, physician recommended medication, physician discussed quitting methods | Older Adults | 3
Egede, 2010: Longitudinal differences in glycemic control by race/ethnicity among Veterans with type 2 diabetes^112^ | Diabetes | 8813 | Quality | Mean change in A1c, odds of poor control (A1c >8%) | Mixed/ Unclear | 0
Egede, 2011: Longitudinal ethnic differences in multiple cardiovascular risk factor control in a cohort of US adults with diabetes^113^ | Cardiovascular disease, Diabetes | 11203 | Quality | CV risk factor control (glycemic, BP, LDL-C) | None Found | 1
Elhai, 2008: Outpatient medical and mental healthcare utilization models among military Veterans: results from the 2001 National Survey of Veterans^33^ | Utilization (outpatient medical and mental health) | 20048 | Utilization | Number of outpatient healthcare visits (VA and non-VA) and receipt of mental health services | Mixed/ Unclear | 2
Fasoli, 2010: Predisposing characteristics, enabling resources and need as predictors of utilization and clinical outcomes for Veterans receiving mental health services^280^ | Mental health (multiple) | 421 | Utilization | Mental health utilization (outpatient, inpatient, residential) | Mixed/Unclear | 2
Fasoli, 2010: Predisposing characteristics, enabling resources and need as predictors of utilization and clinical outcomes for Veterans receiving mental health services^280^ | Mental health (multiple) | 421 | Health Outcome | GAF, self-reported mental health (BASIS-24) | Mixed/Unclear | 2
Frueh, 2007: Age differences in posttraumatic stress disorder, psychiatric disorders, and healthcare service use among Veterans in Veterans Affairs primary care clinics^354^ | Mental health (PTSD) | 745 | Health Outcome | PTSD diagnosis (CAPS), PTSD severity | Younger Adults | 1
Gerber, 2015: Hormone therapy use in women Veterans accessing Veterans Health Administration care: a national cross-sectional study^130^ | Women's health (hormone therapy) | 157195 | Quality | Prescription of hormone therapy | Mixed/ Unclear | 3
Gordon, 2014: Examining patients' trust in physicians and the VA healthcare system in a prospective cohort followed for six-months after an exacerbation of heart failure^134^ | Cardiovascular (heart failure) | 159 | Quality | Trust in VHA | Older Adults | 2
Grubaugh, 2009: Equity in Veterans Affairs disability claims adjudication in a national sample of Veterans^139^ | Disability | 20048 | Quality | Disability benefits | Older Adults | 2
Harris, 2010: Associations between AUDIT-C and mortality vary by age and sex^288^ | Mental health (serious mental illness) | 225092 | Health Outcome | 2-year mortality risk | Mixed/ Unclear | 3
Haskell, 2008: Determinants of hormone therapy discontinuation among female Veterans nationally^141^ | Women's health (hormone therapy) | 36222 | Quality | Hormone therapy discontinuation | Younger Adults | 2
Hawkins, 2012: Prevalence, predictors, and service utilization of patients with recurrent use of Veterans Affairs substance use disorder specialty care^293^ | Mental health (substance use disorder) | 1640 | Utilization | Utilization of substance use disorder specialty services following an index encounter | None Found | 0
Heidenreich, 2009: Disparities in VA heart failure care^148^ | Cardiovascular (heart failure) | NR -likely large | Quality | Guideline-concordant heart failure care | Older Adults | 2
Ho, 2006: The association between processes, structures and outcomes of secondary prevention care among VA ischemic heart disease patients^355^ | Cardiovascular health | 14114 | Quality | Concordance with LDL-C and blood pressure guidelines | Older Adults | 2
Hou, 2012: Myelosuppression monitoring after immunomodulator initiation in Veterans with inflammatory bowel disease: a national practice audit^152^ | Gastroenterology (IBD) | 6045 | Quality | WBC monitoring | Older Adults | 1
Hundt, 2014: Predisposing, enabling, and need factors as predictors of low and high psychotherapy utilization in Veterans^295^ | Mental health, Utilization | 130331 | Utilization | Psychotherapy utilization | Mixed/ Unclear | 3
Irmiter, 2007: Reinstitutionalization following psychiatric discharge among VA patients with serious mental illness: a national longitudinal study^158^ | Mental health (serious mental illness) | 35527 | Health Outcome | Time to reinstitutionalization/ rehospitalization | None Found | 1
Kales, 2010: Who receives outpatient monitoring during high-risk depression treatment periods?^162^ | Mental health (Depression) | 494673 | Utilization | Number of outpatient visits following mental health hospitalization or outpatient initiation of antidepressant medication | Older Adults | 3
Kilbourne, 2006: Quality of care for substance use disorders in patients with serious mental illness^167^ | Mental health (substance use disorder) | 8083 | Quality | Identification of substance use disorders, initiation of treatment, engagement in treatment | Mixed/ Unclear | 1
Kilbourne, 2008: Guideline-concordant hepatitis C virus testing and notification among patients with and without mental disorders^168^ | HCV | 19397 | Quality | Receipt of HCV testing, notified ≤60 days | Younger Adults | 2
Kilbourne, 2008: Guideline-concordant hepatitis C virus testing and notification among patients with and without mental disorders^168^ | HCV | 19397 | Health Outcome | HCV positive | Older Adults | 2
Kimerling, 2011: Military sexual trauma and patient perceptions of Veteran Health Administration health care quality^170^ | Mental health (military sexual trauma) | 164632 | Quality | Patient satisfaction with VHA outpatient care | Younger Adults | 2
Landrum, 2012: Reasons for underuse of recommended therapies for colorectal and lung cancer in the Veterans Health Administration^180^ | Cancer | 584 | Quality | Access, recommendation and receipt of recommended cancer therapy | Older Adults | 1
Lehavot, 2015: Posttraumatic stress disorder symptom severity and socioeconomic factors associated with Veterans Health Administration use among women Veterans^356^ | Mental health | 617 | Utilization | Utilization of VA healthcare within past year for patients with PTSD | None Found | 0
Mattocks, 2015: Infertility care among OEF/OIF/OND women Veterans in the Department of Veterans Affairs^187^ | Women's health (Reproductive health) | 1323 | Quality | Received an infertility assessment | None Found | 0
Mohamed, 2008: Pharmacotherapy for older Veterans diagnosed with posttraumatic stress disorder in Veterans Administration^357^ | Mental health (PTSD) | 244947 | Quality | Receipt of psychotropic medication | Mixed/ Unclear | 3
Partin, 2010: The interrelationships between and contributions of background, cognitive, and environmental factors to colorectal cancer screening adherence^358^ | Cancer (colorectal) | 2416 | Quality | Colorectal cancer screening adherence | Younger Adults | 1
Plomondon, 2007: Severe mental illness and mortality of hospitalized ACS patients in the VHA^359^ | Cardiovascular (Acute Coronary Syndrome) | 14194 | Health Outcome | 1-year all-cause mortality, combined 1-year all-cause mortality/re-hospitalization | None Found | 2
Pogach, 2013: Interplay of chronic illness, race, age and sex in glycemic control^360^ | Diabetes | 79249 | Quality | Glycemic control | Younger Adults | 2
Pugh, 2006: Assessing potentially inappropriate prescribing in the elderly Veterans Affairs population using the HEDIS 2006 quality measure^205^ | Geriatrics, prescribing | 1096361 | Quality | Potentially inappropriate prescribing based on HEDIS criteria | Older Adults | 3
Rawaf, 2007: Exploring racial and sociodemographic trends in physician behavior, physician trust and their association with blood pressure control^209^ | Cardiovascular disease | 793 | Quality | Blood pressure control | Older Adults | 1
Rogers, 2014: Healthcare utilization following mild traumatic brain injury in female Veterans^212^ | Preventive and ambulatory care | 12144 | Utilization | Healthcare utilization, outpatient | Younger Adults | 2
Runnals, 2013: Self-reported pain complaints among Afghanistan/Iraq era men and women Veterans with comorbid posttraumatic stress disorder and major depressive disorder^303^ | Pain, Mental health (PTSD, MDD) | 1614 | Health Outcome | Pain: back, muscle, and headaches | None Found | 0
Sambamoorthi, 2010: Depression treatment patterns among women Veterans with cardiovascular conditions or diabetes^218^ | Women's health (women Veterans with cardiovascular conditions or diabetes) | 8147 | Utilization | Services: antidepressants, psychotherapy | Older Adults | 0
Sambamoorthi, 2012: Decomposing gender differences in low-density lipoprotein cholesterol among Veterans with or at risk for cardiovascular illness^219^ | Cardiovascular (lipid management) | 527568 | Quality | LDL-C greater than or equal to 130 | Mixed/ Unclear | 3
Seal, 2011: Substance use disorders in Iraq and Afghanistan Veterans in VA healthcare, 2001-2010: Implications for screening, diagnosis and treatment^226^ | Mental health (substance use disorder) | 456502 | Health Outcome | Presence or absence of substance use disorders (alcohol or drug use disorder) | None Found | 3
Shaw, 2014: Posttraumatic stress disorder and risk of spontaneous preterm birth^227^ | Women's health (preterm birth), mental health (PTSD) | 16334 | Health Outcome | Spontaneous preterm birth | None Found | 2
Spoont, 2015: Are there racial/ethnic disparities in VA PTSD treatment retention?^231^ | Mental health (PTSD) | 6788 | Quality | PTSD treatment retention | Older Adults | 2
Tseng, 2007: The association between mental health functioning and nontraumatic lower extremity amputations in Veterans with diabetes^237^ | Diabetes | 114890 | Health Outcome | Major and minor non-traumatic lower extremity amputations | None Found | 3
van Ryn, 2014: Patient-reported quality of supportive care among patients with colorectal cancer in the Veterans Affairs Health Care System^361^ | Cancer (colorectal) | 1109 | Quality | Receipt of help for: bowel problems, pain, fatigue, depression, and other physical symptoms | Older Adults | 1
Washington, 2011: Access to care for women Veterans: delayed healthcare and unmet need^362^ | Access | 3608 | Utilization | Delays in obtaining needed healthcare and instances of going without needed care in the prior 12 months. | Younger Adults | 0
Zeber, 2007: Self-reported access to general medical and psychiatric care among Veterans with bipolar disorder^249^ | Mental health (Bipolar) | 435 | Utilization | Patient perception of access to health and mental health | None Found | 0
Zullig, 2013: Examining potential colorectal cancer care disparities in the Veterans Affairs health care system^256^ | Cancer (colorectal) | 2022 | Quality | Guideline-concordant care | Older Adults | 1
Zullig, 2013: The association of race with timeliness of care and survival among Veterans Affairs health care system patients with late-stage non-small cell lung cancer^257^ | Cancer (non-small cell lung carcinoma) | 2200 | Quality | Guideline-concordant care | None Found | 1
Zullig, 2013: The association of race with timeliness of care and survival among Veterans Affairs health care system patients with late-stage non-small cell lung cancer^257^ | Cancer (non-small cell lung carcinoma) | 2200 | Health Outcome | Survival | Older Adults | 1